# Chapter 4—Staffing Issues and Guidelines

As is true with all human service agencies, an intensive outpatient treatment (IOT) program for treating alcohol and other drug (AOD) disorders is only as good as its staff. A program operated by a staff that is uncoordinated and fragmented, uncooperative and independent, unsupportive and unsupported, and lacking in optimism, inspiration, and trust will foster client treatment experiences that have the same qualities. Programs that have these characteristics are unable to provide quality care.

In contrast, an AOD treatment program that is operated by a staff that is coordinated and unified, cooperative and interdependent, mutually supportive and effective at communication, and grounded in optimism, inspiration, and trust will help foster a treatment environment that is conducive to patients' biopsychosocial health. A staff and treatment program with these characteristics can typically provide exceptional treatment services.

Since AOD treatment is intrinsically demanding and stressful work, it is critical that treatment programs provide active and vigorous support for staff members. It is always the quality of the therapeutic alliance that influences patient experience and outcome. Therefore, programs must support staff in a way that allows staff to establish and maintain effective therapeutic bonds with clients.

With regard to staffing issues, intensive outpatient treatment programs have several characteristics that distinguish them from traditional outpatient treatment and medically managed inpatient programs. For example, IOT programs provide treatment to many patients who have left the heavily supervised and restricted environment of an inpatient setting for the less restricted environment of an IOT program. Potent medical, psychiatric, emotional, and social crises may have only recently occurred, and may yet be unresolved. There is not the benefit of shift staff to manage patient care, a problem that creates a great deal of pressure on IOT staff to handle extraordinary patient care issues.

IOT programs often provide services during evening and weekend hours. During periods of limited staffing, supervisors and staff must be flexible and responsive. IOT programs often have part-time staff and contract personnel, demanding special supervision to ensure continuity of services. Because of the nature of IOT programs, it is essential that staff members communicate effectively with one another. They must be able to adapt easily to changing situations.

## Staff Member Roles

IOT treatment staff assignments and responsibilities vary according to the size of the individual program. In larger programs, some clinical services may be provided by specialists. In smaller programs, it is likely that some staff members will need sufficient training to provide comprehensive services.

IOT programs offering distinctive treatment components such as medically managed detoxification, family therapy, and recreation and leisure activities may require specialists such as physicians, family therapists, and certified recreation therapists.

Programs also have different sources from which to draw staff. A hospital-affiliated program, for example, can draw from the hospital's medical, nursing, social work, and other personnel. But many programs are freestanding, or affiliated with an institution without the broad range of services that a hospital can offer.

Personnel in an IOT program can be categorized into three groups:

- Core clinical staff provide direct client treatment services such as assessment, counseling, case management, medical examinations, crisis interventions, and nursing care, as well as clinical supervision.
- Administrative, clerical, and support staff perform administrative functions such as program planning, financial management, logistical support, recordkeeping, contracts management, and management of regulatory compliance.
- Consultant and auxiliary personnel are often outside consultants who provide a range of specialized services including vocational counseling neuropsychological testing, pastoral counseling, and HIV/AIDS education.

The professionals listed below may constitute the core clinical staff. The skills of many of these providers may overlap. For example, nurses and social workers may also serve as addiction counselors. As the AOD field progresses, less attention will be given to training orientation and membership in a particular discipline, and more to overall competency in addictions treatment. All of these staff have a vital role in the functioning of an IOT program on a full- or part-time basis:

- Medical staff include physicians such as psychiatrists, family or internal medicine specialists, addiction medicine specialists, and general practitioners; and nurses, nurse practitioners, physician assistants, and other "physician extenders" who provide medical and nursing assessments, examinations, evaluations, pharmacotherapeutic services, and clinical supervision.
- Addiction counselors provide assessments, individual and group counseling, education, case management, and transition and discharge planning.
- Social workers and other licensed professional counselors provide assessments; individual, group, and multifamily counseling and therapy; education; case management; and transition and discharge planning; they facilitate and make community linkages and provide clinical supervision.
- Psychologists provide individual and group therapy, psychological testing, neuropsychological testing, other assessments, and clinical supervision.

Core staff are often able to provide certain specialized services that may enhance the IOT program. Similarly, auxiliary or consulting staff can be used for program enhancement and may include the following:

- Vocational rehabilitation counselors
- Recreational therapists
- Art, speech, dance, and music therapists
- Nutritionists and dieticians
- HIV and AIDS specialists
- Clergy and pastoral counselors
- Literacy and general equivalency diploma (GED)instructors
- Patient advocates.

Clerical staff members have very important roles in an IOT program. Clerical and support staff are often the first individuals to have contact with potential clients. The nature of this interaction can often lead to successful client placement. Additionally, administrative staff ensure the effective logistical operation of the program. Without their participation, there would be no program. Such staff are also responsible for communicating information about the IOT program to potential patients or referral sources. These individuals should not be taken for granted and should be viewed as members of the team. It is important that they receive education and training regarding AOD abuse, the nature of the IOT program, and confidentiality regulations. They must receive appropriate levels of supervision and support.

In addition, interns and trainees can fulfill several clinical and nonclinical functions. These include physicians and medical students who are participating in an addiction medicine internship; undergraduate and graduate students in clinical psychology, counseling, social work, and addiction studies; and nurses who are participating in an addiction setting placement for a nursing specialty in addiction. Trainees and interns cannot be expected to replace paid staff or provide services that they are not qualified to provide. However, they can be valuable adjuncts to the program and should be incorporated into staff planning. Programs should have written policies and procedures for notifying patients that their care may in part be provided by interns and trainees.

## Shared Knowledge and Beliefs

In addition to specific clinical skills and specialty training, all AOD treatment personnel should share common beliefs and philosophical orientations. First, they should recognize that AOD addiction is a disorder, not a problem caused by moral corruption, emotional deficits, failed willpower, or ignorance. Second, they should recognize that AOD addiction is a biopsychosocial and spiritual disorder not treated effectively or exclusively by any one discipline or orientation, but best treated by a multidisciplinary team of professionals. Third, staff should share the conviction that addiction is a treatable disorder, and that together they can successfully treat people with AOD addiction. Also, staff should share the belief that self-help groups such as the 12-step programs are vital aspects of AOD treatment and recovery.

AOD treatment staff members should be flexible and emotionally mature. They should demonstrate self-awareness, the capacity to relate effectively to others, the capacity to confront and resolve one's own difficulties, self-respect and respect for others, and the willingness to learn about and understand people with backgrounds different from their own.

AOD treatment staff should be willing to listen and understand and have a desire to learn. They should be willing to utilize supervision and mentorship and have an openness to new approaches and orientations. They should be eager to examine their own prejudices and able to avoid overidentification with clients.

Counselors and all professional IOT staff members should be familiar with the following 12 core functions of the AOD counselor:

- Screening
- Intake
- Orientation
- Assessment
- Treatment planning
- Counseling
- Therapy
- Case management
- Crisis intervention
- Patient education
- Referral and coordination
- Reporting and recordkeeping
- Consultation with other professionals with regard to patient treatment and services.

## Clinical Competency Guidelines

The clinical competencies required are somewhat dependent on the specific program, and vary from program to program. In large, heavily staffed programs, not every staff member will have to possess an entire range of skills and competencies.

However, because of the complex needs of clients treated in an IOT program, staff often must be skilled in more than one area of therapeutic intervention. In smaller programs, it is particularly critical that staff members have comprehensive skills and experiences.

### Evaluation and Diagnostic Skills

Staff members should have a clear understanding of the diagnostic signs and symptoms and criteria associated with AOD use disorders. They should be able to conduct a thorough psychosocial evaluation and understand that a diagnosis is not merely a label placed on a patient but a set of hypotheses about the patient's condition. They should understand that the diagnostic process is a framework for determining the problems clients have -- a framework that dictates what treatment is provided.

Staff need to be thoroughly familiar with the current version of the Diagnostic and Statistical Manual of Mental Disorders, (American Psychiatric Association, 1994), which continues to be the professional guide to making diagnoses and treatment decisions, and which is the standard reference for reimbursers and other professionals.

### Documentation Skills

Patients' charts are legal documents and serve several important training functions. The records identify patient issues and serve as the official log to track changes, progress, and case planning. As such, they serve as a vehicle for communication among treatment providers. This is especially critical when the care of a patient is transferred to another provider.

Records are the basis for utilization review, quality assurance, program assessment, and licensure -- to ensure the continued status of the program and the ongoing care of patients. Good recordkeeping is more than a "bureaucratic obligation." It ensures that good care is being provided and records the specific impact of interventions.

For these reasons, chart documentation is a fundamental part of the responsibilities of treatment staff. Training regarding the proper and timely documentation of assessments, interventions, treatment, transition, and discharge is essential for staff at all levels of IOT programs.

### Fundamental Counseling Skills

Certain fundamental and generic counseling skills are needed in all types of therapeutic interventions. These include establishing rapport and the ability to engage and align with the client. Staff and other clinicians should be genuine and nonjudgmental and should treat clients with respect. They should not be threatening and must be able to deal with clients' ambivalence about abstinence. Staff should have the characteristics and skills that relate to empathy, genuineness, respect, self-disclosure, warmth, immediacy, concreteness, confrontation, and change.

Staff should also have the ability to recognize if counseling and other therapeutic interventions are working or not, and should have an awareness of the client's reaction to the therapeutic process and of their reaction to the client. They should know when it is necessary to seek help from other professionals.

IOT patients are often newly recovering AOD abusers. It is particularly important for the staff to be able to confront them in a nonjudgmental way. Staff must be able to provide information and education despite patients' tendency to deflect information.

Staff must be aware that many therapeutic issues will not be addressed during IOT and that some issues will be addressed partially and incompletely. There may be a lack of time within a specific therapeutic intervention or within the schedule of the IOT program to address some issues fully. Also, many clients will have several problems, such as mental health needs, that require clinical attention. However, addressing some problems should be temporarily postponed until clients are stable with regard to their AOD use disorders. Thus, staff will often need to orchestrate the level of intensity of therapeutic interventions and allow sufficient time for individual clients to reach closure on an issue (even if temporary) before the clients leave the premises.

Staff should also have the ability to integrate therapy with events occurring in their clients' lives. Staff should be comfortable becoming involved with the clients' family, employer, and community.

Staff should be able to work with a team and be willing to assume and relinquish authority when necessary. They should have appropriate training for working with people from different ethnic and cultural groups. Staff must have a commitment to using community resources, and to active networking and relationship building to develop a community network of treatment and social services.

Staff members who are recovering from AOD addiction should be trained to serve as AOD professionals. They should be educated about not overidentifying with patients. Recovering staff members should not expect a patient to respond to treatment in the same manner as they did. They need to be comfortable with a patient's developing a different set of recovery skills and resources than their own.

### Individual Counseling Skills

Competencies needed for individual counseling include general listening, reflecting, paraphrasing, and solution-oriented, problem-solving skills. Staff also need the ability to establish rapport, to regulate the intensity of the session, and to manage the therapeutic boundaries of the relationship. Staff should also have the competence to recognize and resolve transference and countertransference issues and to confront denial and resistance. Staff should seek regular consultation on these issues from their supervisor.

### Group Therapy Skills

Staff involved in group therapy must know the difference between group therapy and group support. They must understand the purpose of "here-and-now" group therapy and group process dynamics. They should be able to use the group to facilitate confrontation when necessary and to move the group from a psychoeducational to an interactional mode and back again when necessary. Flexibility is especially important in facilitating the interactive process.

Staff members must have the ability to structure and actively facilitate the early recovery group, until the group demonstrates the capacity to organize itself. Staff members should be able to use the group to advance the overall goals of treatment such as achieving abstinence, solving problems, improving social skills, resolving conflicts, effectively expressing emotions, developing trust, and cooperating with others.

Group counselors must understand the dynamics of addiction, especially the generally potent defense mechanisms that prompt clients to avoid rather than confront issues. Staff should be familiar with denial, minimization, resistance, projection, and other manifestations of an addicted person's defense mechanisms, and should develop ways to address these defenses using the group process.

In contrast to other settings, IOT group facilitators should be more active, directive, and responsive to client resistance. The group must be client centered, but with the counselor playing an active role, especially early in the group's development.

The ability to manage clinically difficult patients is an important attribute. Staff are likely to encounter patients who are still using AODs, patients who are withdrawn, patients trying to take over the group, cognitively impaired patients, and patients with active psychiatric illness.

Staff should understand that change takes time. They should also know that facilitating a seemingly unproductive group session does not mean that the process is ineffective. It is also important for staff to be able to work with a cofacilitator, which involves planning and responding to the group process. Ideally, cofacilitators meet before and after group sessions to discuss the day's group experience. Because of the special advantages of two-therapist groups, cofacilitators are recommended for all outpatient groups.

### Family Therapy Knowledge

Staff members who participate in family therapy sessions or multifamily therapy sessions should have knowledge of and supervised experience with systems-based family therapy methods and techniques. Family interventions are key to outpatient work. Thus, it is recommended that all IOT counselors have some contact with family work.

A traditional family therapist may work with a family once a week. In IOT, the family therapist needs to go beyond traditional frameworks of family therapy and be able to engage in a variety of other activities related to adaptive family responses to the AOD use that exists in the family. These additional interventions may include multifamily therapy, family educational services, psychodrama, or extended day family treatment services. Family therapists in the IOT setting should be trained and skilled in a variety of intervention techniques. Family specialists working with AOD clients should have a thorough knowledge of adjunct family supports such as Al-Anon and Naranon.

### Case Management and Teamwork

IOT program staff members work with many other people in order to accomplish their goals. Thus, communication skills are vital. Open and regular communication among team members is crucial. There must also be communication between program staff and the other community resources that serve clients. Staff must be able to relate to medical and psychiatric staff so that they can work in concert.

The two primary functions of case management are to ensure that patients receive the services that they need -- when they need them -- and to ensure that they experience a continuity of treatment despite changes in treatment programs, changing needs for medical and social services, and other changes in their lives.

IOT staff members involved in case management must serve as liaisons among treatment providers, third-party reimbursement sources, social services, and community resources. They must have a thorough knowledge of available medical, psychological, addiction, religious, spiritual, and social services.

### Multidisciplinary Teams

Because of the biopsychosocial and spiritual nature of addiction treatment and recovery, and because of the diversity of client needs, multidisciplinary teams are essential in the IOT setting. No single profession incorporates the breadth and depth of resources and skills needed to adequately address the wide range of issues of IOT clients and their families.

Staffing should be based on an appreciation of the philosophy of the multidisciplinary team approach and a respect for all disciplines and their contribution to the treatment process. The size of teams varies according to the facility, but the following services should be included in some way:

- Medical services
- Counseling
- Case management
- Social and family services
- Psychological services
- Psychiatric services
- Other ancillary services.

Decisionmaking in the treatment of the IOT patient should be a group endeavor, where input from the various disciplines is considered in assessing progress in recovery. The team is the unit that will assess and chart progress and do treatment planning. The team should function cooperatively, with open communication, with the best interests of clients always being the focus.

The team should have regularly scheduled meetings. Also, ongoing communication among team members outside of formal meetings is critical, especially since some patients' problems require immediate or rapid resolution.

### Working Knowledge of Self-Help Programs

Staff in IOT programs should understand the philosophy of 12-step and other self-help programs, how these programs work, and how they relate to IOT treatment services and any other treatment in which the client may become involved. Besides understanding the philosophy, purpose, and function of self-help programs, they must understand several practical issues. These include:

- The common resistances that people have to participation in 12-step and other groups
- A knowledge of local meetings so that patients can be referred to groups that meet their individual needs
- The function and importance of sponsorship and how to incorporate sponsorship-seeking in the treatment plan
- The differences among 12-step group meetings, such as open and closed meetings, speaker and step meetings, nonsmoking meetings, and meetings for people from special groups, such as men, women, gay men, lesbians, and youth.

There are important distinctions between professional AOD treatment and nonprofessional adjuncts to treatment such as the self-help groups. Professional staff must be able to understand them and to explain these differences to a client.

### Crisis Management

Crisis management is one of the core functions of AOD counselors, a function that is particularly pertinent to the special needs of patients in an IOT program. It can be approached in two ways: staff members can have the crisis response skills necessary to handle a crisis themselves or they can develop the necessary community relations to rapidly obtain the appropriate resources as soon as a crisis develops or seems imminent. Both approaches should be a part of IOT staff training in crisis management.

The ability to manage a crisis should be considered when hiring personnel for the IOT setting. Necessary skills include sound judgment; the ability to think, assess, and respond appropriately; and the ability to assess and stabilize a psychological, social, or medical crisis. Sometimes the skill required is as simple as knowing when to call 911. Other important traits are knowing how to stay out of dangerous situations, knowing when to let go of an issue if a potential crisis is escalating, and understanding one's personal limitations.

Programs should have an explicit written protocol about handling crisis situations. All staff members should be familiar with the protocol.

## Ethical Guidelines

Adherence to professional ethics is important for staff members of all intensive outpatient treatment programs. Personnel working in IOT settings should have a demonstrated commitment to the ethical standards of their profession.

Each individual profession represented in IOT has its own professional code of ethics, and these form the basis for identifying and managing ethical issues. Within the complex IOT context, it is important that counselors and other professionals not go beyond the bounds of their training and experience in the services they provide. Another important point to emphasize is that staff are expected to adhere to ethical standards regarding contact with clients. There should be clear program guidelines on staff contact with patients outside the program since it is inevitable that staff will see clients away from the program. This may be particularly likely for staff who participate in community self-help groups.

Because of the open and unstructured nature of IOT, and the necessity to sometimes work in isolated settings, counselors may be particularly susceptible to charges of misconduct. The program must have clearly stated ethical standards of staff-patient relationships. Whenever possible, at least two staff members should be on site whenever patients are present.

The program must have a protocol for reviewing untoward incidents or complaints and for documenting reports. These incidents must be handled immediately after they happen.

## Staffing Level Guidelines

Because IOT programs vary widely, it is impractical to state specific guidelines for staffing levels or patient-to-staff ratios. However, it is equally important to emphasize that staff in an effective IOT program must be capable of providing intensive, high-level, and responsive services. IOT needs clearly differ from those of other programs with respect to staffing levels. AOD patients have traditionally been served in inpatient facilities, with 24-hour coverage and the support staff associated with an inpatient setting. Although IOT programs require lower staff-patient ratios than outpatient programs that are less group oriented and less structured, there should be sufficient staffing to ensure that no client will go unnoticed and unattended. This is especially critical with respect to the particular challenges cited in Chapter 3. This consideration to patient care should be given within the context of what staff can reasonably accomplish within the parameters of the paid work schedule. For example, a 20-hour part-time employee should not be given caseload responsibilities requiring 40 hours.

A number of variables should be considered in establishing counselor caseloads, including the type of care provided and the availability of auxiliary services. Some States may have regulations governing staff-to-client ratios. These issues must be addressed on a program-by-program basis.

A program should establish clear standards associated with clinical care time to support task rates. A proposed ratio for primary therapists is 50-50: 50 percent of their time engaged in clinical patient contact, and the other 50 percent doing support work related to patient services, such as recordkeeping and community networking. This ratio should be applied to clinical work only, not to supervision or other work clinicians might sometimes perform.

Establishing an ideal time-use ratio is recommended for staff well-being and burnout prevention. However, considering the intense needs of IOT clients, this is an ideal that frequently cannot be met because considerable time is often spent in direct patient care. The size of the IOT program staff, the clinical needs of patients, and the availability of backup services must all be factored into this formula.

## Staff Stressors

IOT work and the nature of the population being treated can cause significant stress among staff. This stress can sometimes be an impediment to running the program successfully. Training front-line and supervisory staff about these stressors can help diminish some problems and help staff prevent or effectively address other problems as they arise.

Staff in different programs will face different dilemmas, and each program must develop its own way of dealing with stressors. In all but the smallest programs, regular meetings to process the concerns of staff members are recommended. Regular meetings should also be held to address the problems of support personnel, who may face different stressors -- sometimes because of the pressures placed on clinical staff. Problems should be addressed as early as possible.

For example, holding a meeting at the end of a stressful day allows staff members to communicate their feelings and express problems and complaints before another work day begins. Staff members should be encouraged to ask for such meetings whenever there is a need.

Some significant stressors that should be anticipated include:

- Long hours and inconsistent work schedule. The demands of clinical coverage in IOT programs often involve evening and weekend hours for virtually all staff members, which can result in staff members feeling isolated from colleagues and support services. Sometimes staff members are required to work broken day shifts, which, like evening and weekend schedules, can interfere with family life.
- Demands of an AOD treatment population. The acute manifestations of AOD abuse and the stress faced by clients, their high risk for crises and sometimes unpredictable behavior, and the intense nature of the treatment environment can create significant stress for counselors and other staff members. The infrequent opportunities for staff members to share their experiences with other peers can lead to isolation, frustration, anger, fatigue, and a sometimes overwhelming sense of responsibility and feelings of helplessness.
- Large caseloads. IOT programs often require a lower staff-to-patient ratio than other outpatient programs. High caseloads can be detrimental to the program. Having smaller caseloads can prevent staff members from being overwhelmed by the demands of the job. This is especially critical in many programs that have to operate with smaller staffs than they actually need.
- Time involvement. Extensive case management time and effort are needed because of the complex issues and needs of AOD clients. These include patient retention efforts and networking with other providers, including employee assistance programs and employers, social service agencies, mental health care providers, and the criminal justice

system. Issues such as relapse, patient employment problems, psychosocial conflicts, after-hours crises, and family problems often complicate treatment and must be handled by the treatment team.

- Limited resources. Limited community resources and supports further complicate treatment in some areas. Clinical staff are required to make extra efforts for nontraditional AOD abuse treatment tasks, which can include vocational placement, housing assistance, and transportation assistance.
- Coordination with managed care providers. Coordinating treatment with managed care providers is a recent addition to some counselors' job descriptions. This responsibility can be an additional stressor. Staff members may feel that pressures from managed care providers conflict with efforts to help patients, and reimbursement may be exhausted long before the counselor feels the treatment process should be concluded.

Some of these stressors can be addressed by the team approach, which can promote shared responsibility and personal support. It is imperative to have a full spectrum of clinical support services available on short notice, and it is also imperative that clinicians know when and whom to ask for help.

IOT Staff Stressors

- Long hours and inconsistent schedule
- Client demands
- Large caseloads
- Extensive time involvement
- Limited resources
- Coordination with managed care.

## Recommended Staff Supports

Stresses involved with IOT work are significant and should not be underestimated. However, they can be resolved, and programs can develop a work culture and personnel policies and procedures that enhance staff retention, avoid burnout, and keep the program functioning at a level that provides high-quality care.

It is important to note that a program should be committed to having as much regard for its staff members as it does for its clients. Again, the most essential and indispensable resource of a program is its staff.

### Program Philosophy and Description

As discussed above, a fundamental aspect of an effective treatment program is the establishment of a program philosophy and a description of the population served and how the program serves it. The program philosophy and description should incorporate a clear mission statement, congruent with the day-to-day practice of the program.

This written document relates to staff performance and expectations because it defines standards for effective and ethical treatment interventions, and it defines the relationship between clinician and client. It provides boundaries for counselors. The program philosophy should provide standards and guidelines for the well-being of staff, and support the staff by giving them clear guidelines and goals for acceptable and desired standards of care and defined roles.

IOT is community-based treatment, and the program statement should address professional relationships within the community, as well as the purpose of treatment, expected outcomes, and strategies for accomplishing these objectives. The philosophy gives the program a clear sense of what it is supposed to do and expresses its reason for being.

The philosophy and program statement should be a dynamic document and should be regularly reviewed and discussed, since a program is constantly developing, changing, and adding new staff. It should be flexible enough to be open to new input at any time, and all staff members should be encouraged to contribute to it on an ongoing basis.

### Job Description

It is important that all permanent and auxiliary clinical and administrative staff members have a clear and complete job description that includes job expectations, responsibilities, and specific functions. Job descriptions should be the basis for performance evaluations, with clearly defined expectations and performance levels. These performance indicators should be measurable and should change as the responsibilities of the program and the capabilities of the staff change.

### Shared Ownership

Shared ownership of the program is an important concept that empowers staff members by having them share accountability for the program. This means that all staff feel credited when the program succeeds and that everyone participates in its development and operation. Management in such a setting is participatory rather than hierarchical. Shared ownership protects the integrity of the program.

Situational methods such as program retreats or planning sessions should be established to allow staff to have responsibility for input into program design and development. Support to the staff can be further realized by extending the ownership of the program to the patients it serves by offering a strong therapeutic involvement (e.g., the use of multifamily therapy groups). Strong patient involvement enhances clinical responsiveness while reducing patient reliance on staff.

### Appropriate Recognition

Another important staff support is appropriate recognition, which should occur at all levels. Good management means acknowledging successes as well as shortcomings. This is a skill that every supervisor should have, to avoid being solely problem centered. IOT supervisors should be skilled at recognizing staff effort and accomplishments outside of the normal appraisal process. The supervisor should acknowledge work well done at times other than performance review time.

### Promotion

Another form of recognition is promotion. Managers should be encouraged to promote from within whenever possible. They should actively encourage employees to continue their education and should facilitate these efforts by posting information about educational programs and events and providing a reasonable subsidy for participation in them. Staff should be made aware of the potential for advancement within the program or in other settings if exceptional opportunities exist. Employees should be valued for their potential as well as their actual contribution to a program.

### Appropriate Compensation

Fair and competitive compensation for a job is an appreciated means of staff support from the employee point of view. Even though there may currently be a larger pool of human resources than positions in the field, it is important that people be paid an adequate and reasonable wage that is commensurate with their experience and qualifications.

Establishing commensurate levels of compensation cannot be adequately addressed in this document. Pay scales vary widely from region to region across the country. A program has the responsibility to hire someone who is adequately trained, and compensate that person appropriately, consistent with the competitive context of the position and the compensation available for similar positions in other programs. Such actions are not only in the interest of the employee, but also in the long-term interest of the clients and the program.

A certain level of salary does not guarantee a competent staff or effective treatment, but if people are paid below community and professional standards, or are exploited, they will not likely remain with the program. Frequent employee turnover is a sign of poor personnel practices.

### Flexible Work Schedules

In an IOT setting, the commitment to flexible work schedules is critical to recruiting and retaining good staff. Flexible work schedules can help staff members accommodate their personal needs and make stronger commitments to the demands of the job. Whenever possible, schedules should be open to change and negotiation. Supervisors should be sensitive to the difficulties of single parents and other family issues and to other personal considerations that make a difference in staff morale. Larger programs may be better equipped than smaller ones to offer flexibility and rotating responsibilities. Flexible schedules are also particularly relevant to IOT programs that use part-time and/or contractual help. The nature of IOT work, which requires evening and weekend staff coverage, can add to the flexibility of scheduling that a staff member may find personally helpful. For example, some employees with children may prefer evening and weekend work, so that they can share child care responsibilities with a spouse who has a conventional work schedule.

This flexibility, of course, must be balanced with the needs of the program. But often what works best for the individual employee works best for the program.

### Ongoing Supervision and Training

Ongoing supervision and training are also recommended staff supports. Supervision must be consistent and regular, on both individual and group levels. Clinical supervision for most staff should be scheduled at least once a week, with a clinician with qualified clinical and supervisory experience, plus additional sessions on an as-needed basis. Special attention should be paid to the supervision of part-time staff, who depend on the supervisory process to ensure continuity of services.

Staff development opportunities should be available as much as possible, allowing professional personal leave days to participate in workshops, training sessions, and other professional activities. Support for staff training should be considered in the development of the program budget, and a reasonable allocation should be given to professional development activities. The 1993 Substance Abuse Prevention and Treatment Block Grant requirements include mandates requiring entities receiving funds to provide continuing education to staff appropriate to the services that they provide. The focus of professional development activities should be on learning new information and skills that might lead to program enhancement and more broadly focused care and competency. Given the nature of IOT, staff efforts to participate in activities such as stress management workshops should be encouraged.

Supporting IOT Staff

- Provide a clear program philosophy and description
- Encourage shared ownership of the program
- Provide appropriate staff recognition (promotion and compensation)
- Allow flexible work schedules
- Provide ongoing supervision and training
- Encourage team building
- Encourage peer assistance.

An important part of staff training is attention to culturally sensitive issues. All programs should have a commitment to provide this training. Culturally diverse groups and issues include:

- Gender issues
- Age issues
- People from lower socioeconomic backgrounds, including homeless persons and those with housing instability
- Rural and urban populations
- African Americans
- Hispanic people
- Native Americans
- Asians and Pacific Islanders
- Asian Americans
- Gay men
- Lesbians
- Physically challenged people.

Exhibit 4-1 is a list of written materials and sources for information about cultural sensitivity training.

Exhibit 4-1 Cultural Sensitivity Training Materials and Resources

Cultural Sensitivity Training Materials and Resources

Materials

Sue, D.W., and Sue, D. Counseling the Culturally Different: Theory and Practice, Second Edition. New York: John Wiley & Sons, 1990.

Finnegan, D.G., and McNally, E.B. Dual Identities: Counseling Chemically Dependent Gay Men and Lesbians. Center City, Minnesota: Hazelden Educational Materials, 1987.

Goodchilds, J.D., ed. Psychological Perspectives on Human Diversity in America. Washington, D.C.: American Psychological Association, 1991.

Hidalgo, H., Peterson, T.L., and Woodman, N.J., eds. Lesbian and Gay Issues: A Resource Manual for Social Workers. Silver Spring, Maryland: National Association of Social Workers, Inc., 1985.

Weinstein, D.L., ed. Lesbians and Gay Men: Chemical Dependency Treatment Issues. Binghamton, New York: Haworth Press, Inc., 1992.

Agency

Technical Assistance Center, Institute on Black Chemical Abuse, 2616 Nicollet Avenue, Minneapolis, MN 55408, 612-871-7878.

### Team Building

An organized approach to team building is another helpful way to support IOT staff. It is helpful to have daily processing time for counselors to discuss and analyze the clinical events of the day, particularly after any untoward incident.

Regular retreat sessions are a valuable way of getting away from the stress of the job and concentrating on planning and program evaluation. A retreat also reinforces employees as stakeholders of the program, involved in participatory management and decisionmaking.

Other planned events such as picnics, holiday parties, and structured activities can boost employee morale. However, these social events do not replace the need for ongoing communication and team building throughout the year.

### Peer Assistance

It is also helpful for intensive outpatient treatment programs to have a peer assistance structure to deal with problems such as tragedies on the job. Encouraging peer support, both formally through regular staff meetings to discuss problems and issues and informally by creating a working team, is an important element of an effective program. The promotion of staff wellness should be a priority for IOT programs. In organizations that have them, employee assistance programs can assist staff with the resolution of personal or professional problems.

## Certification and Credentialing

Every program should recognize a certifying body for professional staff, and staff should have a professional development plan. This will ensure compliance with internal privileging standards and those of credentialing bodies such as the National Association of Alcohol and Drug Abuse Counselors, the American Society of Addiction Medicine, and others.

It is also recommended that professionals who are working in the AOD field, irrespective of their specific discipline or the amount of time in AOD treatment settings, receive ongoing training in the treatment of AOD disorders. If the IOT program is the primary setting in which they are working, staff professionals need more than just a working knowledge of the field; they should be able to formally demonstrate AOD treatment competency.

## Recommendations

Regarding the critical issue of staffing IOT programs for AOD treatment, the consensus panel offers the following recommendations:

1. Clinical staff should be knowledgeable about the full spectrum of AOD abuse and addiction. Clinical staff should be certified or licensed, or working toward certification or licensure in their discipline, with special attention given to specific training in the addiction field.
2. The IOT program should be run by a core of clinical staff members who each identify the program as his or her primary job. Although part-time employees are part of many programs, an IOT program should not be run exclusively with them unless it serves a very small or specialized population. The program usually needs a core full-time staff that is responsible for maintaining the continuity of care that the program provides.
3. Ongoing quality supervision that is responsive to the needs of the clinical staff is an important part of the IOT program. Part-time personnel require consistent supervision to ensure adequate support and guidance and consistency of services.
4. Those charged with certain responsibilities should have the authority and resources to successfully meet the expectations of their jobs.
5. Any consideration of IOT staffing must respect the unique stressors and challenges faced by IOT staff, such as working odd hours, working in isolation, and a lack of "third shift" support.
6. Quality IOT programming must be done within the context of multidisciplinary teams.
7. The clinical staff should not be utilized in functions that limit or detract from their ability to provide optimal care for their clients.