# Chapter 1—Introduction

These are times of change and complex challenges for professionals who work in the alcohol and other drug (AOD) abuse treatment field. They are experiencing increasingly intense pressure to provide comprehensive, cost efficient, and high quality care for AOD abuse patients. Government policies appear to be shifting away from a predominant focus on interdiction and toward an emphasis on prevention and treatment. Yet, only limited, overextended, and diminishing resources are available to provide treatment. These changes and challenges are occurring during a time when AOD disorders and their treatment are both increasing in complexity.

As a result, treatment providers are challenged to search for and consider innovative, measurably effective, and less costly approaches to the treatment of people with AOD use disorders. These challenges occur within the context of an evolution in health care policy and changes in the national health care system. Managed care and managed competition are now potent forces in health care and are likely to be important aspects of health care reform. At this time, the long-term impact of yet-to-be-established national health care policies on AOD treatment is unknown. Thus, in the face of advanced complexity of AOD use disorders, treatment professionals can expect to continue to be charged with providing treatment that achieves a balance between cost efficiency and clinical efficacy.

As AOD abuse treatment professionals examine issues of treatment effectiveness and cost, they are growing increasingly aware of the need to provide specialized treatment services for special groups. A few of the many groups that may benefit from special and often complex treatment services include:

- Persons with combined psychiatric and AOD use disorders
- Ethnic and cultural minority group members
- Persons who are homeless or experiencing housing instability
- Clients with the HIV virus or AIDS
- Gay and lesbian clients
- Pregnant women
- Elderly persons
- Those who are involved with the criminal justice system.

A number of these groups are the focus of other TIPs that readers may wish to refer to for an in-depth discussion of the particular problems and treatment of these groups.

One of the most useful responses to the challenges that face treatment providers has been the development of continuum-of-care models that match specific levels of treatment with the individual patient's particular treatment needs. Until recently, two models dominated the field of alcohol and other drug abuse treatment:

- The medically managed 28-day inpatient treatment program, and
- The low-intensity, traditional outpatient service model, which usually offers one weekly session of individual or group therapy.

A critical look at the traditional use of these two models has led to the recognition of a significant gap in the AOD treatment delivery system. In many instances, clients receive too few treatment services and are underserved; others receive more treatment services than they need. In both cases, clients receive the only level of care that is available or that they are able to find.

Further, the treatment of AOD use disorders has historically been fragmented in several ways. For instance, clients often receive a burst of intensive inpatient treatment followed by low-intensity aftercare services that are inadequate and insufficient. Also, patients who require multiple treatment services often must obtain these services at different treatment sites. For example, it is common for patients with combined psychiatric and AOD use disorders to receive psychiatric treatment at one site and AOD abuse treatment at another. Thus, AOD clients in vulnerable conditions often have to accept undue responsibility for coordinating their own care.

One of the responses of AOD abuse treatment providers to these challenges has been the development of the intensive outpatient treatment (IOT) level of care. IOT actually refers to a range of types of organized care. While it is a less intense level of care than inpatient care, IOT nonetheless provides a substantial range of treatment intensity. This level of care has been adapted to several models such as day treatment and evening programs. The IOT level of care is designed to bridge the gap between medically managed or medically monitored intensive inpatient treatment and traditional outpatient services of low intensity.

Although programs that provide AOD abuse treatment at an intermediate level of care have existed to some degree for several years, the widespread development and study of these programs has only recently gained momentum. Pressures from insurance and managed care companies, as well as demands from many sources for more cost-effective publicly funded treatment, have contributed to the growth of IOT programs.

The development and study of IOT programs are complicated by a remarkable variation in the intensity and scope of treatment services provided by IOT programs and a lack of standardization regarding quality of care measures. Standardization of the names and descriptions of intensive outpatient treatment programs does not exist. For instance, some intensive outpatient day treatment programs describe themselves as partial hospitalization programs, while other programs that provide precisely the same services simply call themselves IOT programs. Similarly, there is wide variation in the extent of coverage for intensive outpatient treatment by third-party payers. The variation in coverage by third-party payers may be related to the variations found among IOT programs.

While the need for programs that provide an intermediate level of care seems obvious, the need for program evaluation is less obvious but equally critical. There have been fairly consistent findings of similar patient outcomes for inpatient and outpatient treatment across a range of measures -- findings that support the further development and study of intensive outpatient treatment. Unfortunately, there has not been an organized effort to identify the particular benefits of IOT or to determine the specific elements of IOT that lead to successful outcomes. This Treatment Improvement Protocol (TIP), based on the experience of members of a national multidisciplinary consensus panel, is an initial effort toward meeting such an objective.

## The Purpose of This TIP

There is a need for education about IOT among AOD treatment providers, payers, and people who make referrals for AOD treatment. This TIP provides an introductory review of IOT, documenting the clinical viability and utility of IOT, and stressing the range in IOT services within the broader continuum of care. This TIP describes the rationale for the development, institutionalization, and study of the IOT level of care. It identifies the roles of IOT in relation to the other levels of care, and reviews appropriate and existing patient admission and placement criteria. It describes the essential and desirable components of an effective IOT program. It reviews salient staffing issues and needs associated with IOT programs. Finally, this TIP addresses the special issues and challenges associated with IOT, including the needs of special groups, legal and ethical issues, quality improvement challenges, and reimbursement issues.

The same forces and challenges that have prompted the development of the IOT level of care have promoted a greater awareness of the need for all health care programs to increase cooperation, collaboration, and functional linkages. AOD treatment programs are using assertive case management models to closely monitor patients' treatment across the continuum of care and through multiple service delivery systems. Indeed, AOD treatment programs are increasingly providing a greater range of services and are coordinating closely with other programs that address the needs of AOD clients.

Various challenges, including a heightened accountability to payers, have prompted the development of specific diagnostic and patient placement criteria for assessing the appropriate level of care for patients in AOD treatment settings. Patient placement criteria are instrumental in determining the optimal points for the transfer of patients from one level of care to another. The emphasis given here to intensive outpatient treatment does not suggest that traditional levels of care for AOD disorders are without purpose or efficacy.

IOT programs have gained a reputation for effectively treating highly functioning patients with relatively intact family systems and good psychosocial supports. It must be considered that many of these patients are achieving recovery and experiencing qualitative improvement in their lives not in spite of being treated in IOT programs but rather because of the distinct qualities and advantages of IOT programs. These successes suggest that IOT programs can effectively treat a wide variety of patients who were previously considered treatable only in inpatient settings.

## Advantages of IOT Programs

The IOT level of care has several clinical and consumer advantages. For instance, the cost of IOT treatment is often less than half the cost of inpatient treatment. As a result, IOT treatment is often measured in months rather than days or weeks. This allows patients more time to learn new behaviors, participate in self-help groups, and practice relapse prevention strategies. In an IOT program, patients can continue to function in already-established roles with minimal disruption to work and family life. In fact, work and family life are better stabilized through the support and structure offered by IOT.

The intensity of the IOT level of care promotes close bonding among patients. Access to the world outside of the program increases opportunities to practice learned behaviors and new responses such as drug refusal skills, open communication, and stress reduction techniques. Patients who participate in treatment within a therapeutic setting while returning daily to their home environment can practice relapse prevention techniques in the milieu in which they live. These patients can also be assessed more accurately with regard to their problems and progress. There is a greater opportunity for treatment providers to strengthen patients' psychosocial supports and to intensively intervene within their family systems.

Some IOT programs provide access to noninstitutional housing such as apartments or houses near the program site. Others operate in conjunction with a residential treatment option. In shared housing arrangements, patients experience a milieu similar to the natural living environment. They experience greater responsibility than they would in an institutional setting such as a hospital.

## Underlying Principles Of the TIP

Several principles serve as the foundation for this TIP. In turn, these principles can be incorporated into the philosophy and management of IOT treatment programs.

- Treatment works. The suggestions, recommendations, and shared experiences that are presented in this TIP are based on the premise and documented empirical evidence that therapeutic clinical interventions have a significant impact on AOD use disorders.
- A continuum of care will cost-effectively enhance patient care. The treatment of patients within a continuum of care is the most cost-effective response to the treatment of AOD use disorders. The organized use of a continuum-of-care treatment system allows patients to be matched to the level of treatment they need, with precise transitional services available to meet the changing needs of individual clients. A true continuum of care should allow for longer-term care for clients who need it.
- A multidisciplinary approach is vital. A multidisciplinary approach to the assessment and treatment of patients with AOD use disorders is essential to good patient care. AOD-dependent patients often have several complex problems. The expertise and involvement of specialists from several disciplines are critical for positive patient outcomes. Similarly, a large repertoire of treatment skills and techniques is required to respond to the complex and changing needs of patients.
- Staff should be cross-trained. Despite the need for specialists in various areas, treatment providers should encourage cross-training of staff. Despite dissimilar training backgrounds, clinical staff should share a common treatment and recovery philosophy. Staff education is essential, and programs should schedule regular times for the review and discussion of books and articles on AOD use and treatment, including published research.
- Integration of treatment is essential. It is no longer acceptable to treat one problem at a time and simply refer untreated issues to another provider. Rather, it is essential that treatment be integrated, and that patients receive appropriate care for existing and anticipated addiction, psychiatric, and medical problems. They must also receive the additional support services necessary to achieve problem resolution. Case management services are an important component of AOD treatment. Such services are a particularly important aspect of providing a continuum of care and integrating treatment and other services for IOT patients.
- Treatment should be individualized. No single approach to AOD treatment will work for all patients. Rather, treatment should be individualized for each patient, with special treatment goals to meet the particular needs of each patient. AOD treatment should involve a wide variety of clinical interventions.
- Treatment programs should be accountable. Treatment interventions and decisions should be based on proven, empirically supported outcomes. The optimal care of patients requires a high level of accountability. Models of treatment should be based on proven outcomes, and placement decisions should be based on known rather than assumed benefits to patients.

### Overview of the TIP

#### Chapter 2 -- Placement Criteria and Expected Treatment Outcomes

This chapter defines IOT as a level of treatment and a range of services and intensities that exists in the context of the larger continuum of care. Within the IOT level of care, several different program models can be adapted to numerous settings. The chapter provides a review of these levels of care, a detailed description of the IOT level of care, an overview of admission and placement criteria, and dimensions for assessment based on the Patient Placement Criteria for the Treatment of Psychoactive Substance Use Disorders developed by the American Society of Addiction Medicine (Hoffman et al., 1991). This chapter highlights the importance of individualized treatment planning and the use of specific treatment goals.

#### Chapter 3 -- Components of an Effective IOT Program

To provide a balanced perspective on IOT, this chapter includes a discussion of the rationale for IOT, as well as the advantages, disadvantages, and challenges faced by IOT programs. The chapter describes treatment services that, although not proven to be essential, can be considered core elements of IOT programs, and treatment services that can be considered optimal elements of an enhanced IOT program. Common clinical issues such as retention and relapse are discussed.

#### Chapter 4—Staffing Issues and Guidelines

This chapter provides an overview of human resource issues and program needs associated with an IOT level of care. There is a discussion of the recommended professional qualities of staff members. Guidelines for clinical competency, such as skills for evaluation, counseling, and family therapy and knowledge about self-help resources, case management, and crisis management are outlined. There is also a description of ethical guidelines, professional education standards, staffing level guidelines, and staff stressors. The chapter also recommends specific ways that IOT can be designed to support treatment staff members.

#### Chapter 5 -- The Treatment Needs of Special Groups

This chapter describes the treatment needs of some special groups, including women, cultural and ethnic groups, homeless people, gay men and lesbians, people with HIV or AIDS, elderly patients, persons in the criminal justice system, and patients with combined psychiatric and AOD use disorders.

#### Chapter 6 -- Special Fiscal and Administrative Issues

The TIP includes a discussion of financial issues related to public and private funding, managed care, and program costs. There is also a discussion of quality improvement issues, including guidelines for program evaluation.

#### Chapter 7—Legal Issues for IOT Programs

The final chapter describes some common legal concerns associated with IOT, many of which have ethical implications. There is an overview of the Federal laws and regulations protecting the rights to privacy of people seeking or receiving AOD treatment services. Rules governing the use of consent forms are discussed. This chapter reviews the rules for communicating with others about AOD patients, including how agencies communicate with one another and how programs can warn others of a patient's threat to harm. Exceptions that permit programs to disclose information are described, and practical information about patients' right to confidential services and the use of legal guidance is provided.

## Summary

The development of the IOT level of care is a partial response to many of the changes taking place in the addiction treatment field and throughout the national health care system. This TIP was written to provide information about the IOT level of care; to educate providers, payers, and others about the appropriate use of IOT; to encourage further development of IOT; and to assist IOT providers to evaluate and improve their programs. It is the hope of the consensus panel that this TIP and the further development of IOT will help target the level of care to patients' needs, rather than expecting patients to adapt to levels of care that are more or less intense than required. IOT is a valuable, cost-effective, and clinically effective segment of the continuum of care for AOD use disorders. It is hoped that this document will serve as an impetus toward the further demonstration of the efficacy of a continuum of care and a multidisciplinary approach to the treatment of AOD disorders.