# Appendix D—Field Reviewers

- Bob Anderson
- Director
- Criminal Justice Programs
- National Association of State Alcohol and Drug Abuse Directors

- Doug Baker, C.S.A.C.
- Assistant Section Chief
- Alcohol and Drug Abuse Section
- North Carolina Department of Human Resources

- Richard J. Bast
- Public Health Advisor
- Center for Substance Abuse Treatment

- David Beaman, Ph.D.
- Director
- Substance Abuse and Prevention Services
- Planning District 19
- Community Services
- Board of Substance Abuse Services
- Petersburg, Virginia

- J. B. Bixler
- Executive Director
- Association of Community Mental Health Authorities of Illinois
- Springfield, Illinois

- L. Worth Bolton, M.S.W., A.C.S.W.
- Program Director
- Westhaven Outpatient Treatment Programs
- Raleigh, North Carolina

- Bill B. Burnett, M.Ed.
- Director
- Treatment and Intervention
- South Carolina Commission on Alcohol and Drug Abuse

- Bruce Carruth, Ph.D., L.C.S.W.
- Little Rock Psychotherapy Group
- Little Rock, Arkansas

- Lloyd Crawford, Ph.D.
- Administrator
- Plumas County Alcohol and Drug Program
- Quincy, California

- Dorynne Czechowicz, M.D.
- Associate Director for Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse

- Doris Derrington
- Consultant
- Alcohol and Drug Abuse Services
- Topeka, Kansas

- Jim Dyson
- Director
- Addiction Recovery Center
- Rapid City Regional Hospital
- Rapid City, South Dakota

- Garland Ferguson
- Assistant Director
- Arkansas Division of Alcohol and Drug Prevention

- William J. Filstead, Ph.D.
- Quality Measurements, Inc.
- Arlington Heights, Illinois

- Robert F. Forman, Ph.D.
- Executive Director
- Rehab After Work
- King of Prussia, Pennsylvania

- Peter Frantantuono, Jr., M.A., A.C.D.P.
- Executive Director
- Counseling and Intervention Services
- Rhode Island Substance Abuse Advisory Council
- Warwick, Rhode Island

- Mark Galizio, Ph.D.
- Professor of Psychology
- Department of Psychology
- University of North Carolina, Wilmington

- Anne Geller, M.D.
- President
- American Society of Addiction Medicine

- Deberah Goldman, Ph.D.
- Smithers Outpatient Department
- St. Luke's-Roosevelt Hospital
- New York, New York

- Terence T. Gorski
- President
- Cenaps Corporation
- Homewood, Illinois

- Bruce Hart, M.S., C.A.D.A.C.
- Clinical Coordinator
- Starting Now Intensive Outpatient Treatment Program
- Brattleboro, Vermont

- Jack Harville
- President
- Dilworth Center for Chemical Dependency
- Charlotte, North Carolina

- Bohdan Hrynewych, A.C.S.W.
- Program Coordinator
- Duke Alcoholism and Addictions Program
- Duke University Medical Center
- Durham, North Carolina

- Lotty Inselberg, Ph.D., R.N., C.A.R.N.
- North Woodmere, New York

- George Jacobson, Ph.D.
- Milwaukee Psychiatric Hospital
- Wauwatosa, Wisconsin

- Marco E. Jacome, C.S.A.D.C., C.E.A.P., N.C.A.C. II
- Executive Director
- Healthcare Alternative Systems, Inc.
- Chicago, Illinois

- Gary Q. Jorgensen, Ph.D.
- Director
- Drug and Alcohol Abuse Clinic
- School of Medicine
- University of Utah

- Ruth H. Carlsen Kahn, D.N.Sc.
- Health Manpower Education Specialist
- Division of Medicine
- Bureau of Health Professions
- Health Resources and Services Administration

- Linda Kaplan, M.A., C.A.E.
- Executive Director
- National Association of Alcoholism and Drug Abuse

- Christine L. Kasser, M.D.
- Medical Director
- Baptist Recovery Center
- Memphis, Tennessee

- Julian Keith, M.D.
- Section Chief
- Alcohol and Drug Abuse Section
- North Carolina Department of Human Resources

- George Kolodner, M.D.
- Medical Director
- Kolmac Clinic
- Silver Spring, Maryland

- Tom Kosten, M.D.
- Division of Substance Abuse
- Yale University
- New Haven, Connecticut

- Joel Kostin, Ph.D.
- Regional Director
- Achievement and Guidance Center of America
- Chapel Hill, North Carolina

- Donald P. Loker, N.C.A.C. II, C.A.P.
- 1st Step of Sarasota, Inc.
- Sarasota, Florida

- Bruce Lorenz, N.C.A.C. II, C.A.D.C., C.E.A.P.
- Delaware Drinking Driver Programs, Inc.
- Dover, Delaware

- Mary E. McCaul, Ph.D.
- Associate Professor
- Comprehensive Women's Center
- Francis Scott Key Medical Center
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- David Mee-Lee, M.D.
- Medical Director
- Castle Medical Center
- Honolulu, Hawaii

- Michael M. Miller, M.D.
- Meriter Hospital, Inc./New Start
- Madison, Wisconsin

- Tony Mulvihill
- Director
- Alcohol and Drug Council of North Carolina
- Durham, North Carolina

- Madeline A. Naegle, Ph.D., R.N., F.A.A.N.
- Division of Nursing
- School of Education
- New York University
- New York, New York

- Paul D. Nagy, M.S., C.S.A.C.
- Director
- Substance Abuse Counseling
- Duke University Medical Center
- Durham, North Carolina

- Steven Newman, Ed.D.
- Director
- Substance Abuse Services
- Mecklenburg Mental Health, Developmental Disability, and Substance Abuse Services
- Charlotte, North Carolina

- Jewell Oates, Ph.D.
- Executive Director
- The Women's Treatment Center
- Chicago, Illinois

- Larry G. Osmonson, N.C.A.C. II, C.A.P., C.T.R.T.
- President
- National Association of Alcoholism and Drug Abuse Counselors

- Vincent J. Patti, C.S.W.
- Psychotherapist
- New York, New York

- Larry Petersen, L.C.S.W.
- Salt Lake County Division of Substance Abuse Services
- Salt Lake City, Utah

- Edward Ravine, M.A., C.R.A.D.C.
- Assistant Division Director
- Mental Health Division
- Lake County Health Department
- Waukegan, Illinois

- Fannie Robertson, R.N., M.S., C.D.
- Commission on Public Health of the District of Columbia

- Virginia Ryan, Ph.D.
- Principal Investigator
- Self Help Addiction Rehabilitation
- Detroit, Michigan

- Irv Shandler, Ph.D.
- President/CEO
- Diagnostic and Rehabilitation Center
- Philadelphia, Pennsylvania

- John Shields
- Director
- Medicorp Recovery Network of Winston-Salem
- Winston-Salem, North Carolina

- Michael O. Smith, M.D., D.Ac.
- Director
- Substance Abuse Division
- Lincoln Hospital
- Bronx, New York

- Phillip Spivey, Ph.D.
- Director
- Outpatient Services
- Smithers Alcoholism Treatment and Training Center
- St. Luke's-Roosevelt Hospital
- New York, New York

- Teresa Staley, M.A., N.C.A.C. II, C.A.C. II
- Clinical Director
- Clitheroe Center
- Anchorage, Alaska

- Donald Storms, C.A.C., C.A.D.A.C., C.H.I.V.C.
- Project Coordinator
- Bureau of HIV Program Services
- New York City Department of Health

- Barbara Warren, Psy.D., C.A.C.
- Director
- Mental Health and Social Services
- Lesbian and Gay Community Service Center
- New York, New York

- Arnold M. Washton, Ph.D.
- Director
- The Washton Institute on Addictions
- New York, New York

- Kathy Leigh Willis, C.E.A.P., N.C.A.C. II,
- President
- California Association of Alcoholism and Drug Abuse Counselors