# Appendix C—Federal Resource Panel

- John Ambrose
- Vice President of Public Affairs
- National Mental Health Association

- Jim Brennan
- Staff Associate
- National Association of Social Workers

- William Butynski, Ph.D.
- Executive Director
- National Association of State Alcohol and Drug Abuse Directors

- James Callahan, D.P.A.
- Executive Vice President
- American Society of Addiction Medicine

- Sandra M. Clunies, M.S., N.C.A.D.C.
- Government Project Officer
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse

- Walter L. Faggett, M.D.
- Capital Area Health Services
- Washington, D.C.

- John Gregich
- Acting Assistant Deputy for Treatment
- Office for National Drug Control Policy
- Executive Office of the President

- Tamiko Hamiel
- Association Coordinator
- Drug and Alcohol Nursing Association

- Ruth H. Carlsen Kahn, D.N.Sc.
- Health Manpower Education Specialist
- Bureau of Health Professions
- Health Resources and Services Administration

- Linda Kaplan
- Executive Director
- National Association of Alcoholism and Drug Abuse

- David C. Lewis, M.D.
- Association for Medical Education and Research in Substance Abuse
- Brown University
- Providence, Rhode Island

- Cherry Lowman
- Health Scientist Administrator
- Treatment Research Branch
- Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism

- Robert Lubran
- Senior Advisor for Quality Assurance
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Anna Marsh, Ph.D.
- Associate Director for Evaluation
- Office of Applied Studies
- Center for Substance Abuse Treatment

- Paul Nagy, M.S., C.S.A.C.
- Director Counseling
- Duke Alcohol and Addictions Program
- Clinical Associate
- Department of Psychiatry
- Duke University Medical Center
- Durham, North Carolina

- Cecelia Willis, M.D.
- National Black Alcoholism Council