# Appendix B—Sample IOT Program Schedules

Intensive outpatient treatment (IOT) can be adapted to several different models of treatment programs. Two such models are day treatment and evening treatment.

This appendix includes sample program schedules for a day IOT program and an evening IOT program. Also included is the evening IOT program lecture schedule.

Sample Day IOT Program Schedule

| Monday | Tuesday | Wednesday | Thursday | Friday
8:00 - 8:30 | Meditation & community | Meditation & community | Meditation & community | Meditation & community; weekend preparation | Meditation & farewell to graduates
9:00 - 10:30 | Group therapy | Group therapy | Group therapy | Group therapy | Group therapy
10:45 - 11:30 | Assignment group | Special issues group or multifamily therapy | Orientation group | Assignment group | Assignment group
11:30 - 12:45 | Lunch | Lunch | Lunch | Lunch | Lunch
12:45 - 1:45 | First step evaluation or assignments | Women's or men's group | Experiential group | Leisure & stress group | Women's or men's group
2:15 - 3:30 | Leisure & stress group | Step education | 2nd & 3rd step group | Relapse prevention | Lecture & video
| 4:00 - 5:00 Lecture & video | 4:00 - 5:00 Medical aspects | 4:00 - 5:30 Aftercare meeting | 4:00 - 5:00 Family issues | 4:00 - 5:30 Review of weekend plans
Evening | 12-step meeting | 12-step meeting | Community dinner & 12-step meeting on premises | Men's and women's community meeting & 12- step meeting | 12-step meeting
Note: Individual counseling sessions may be scheduled from 8:00 to 9:00, Monday through Friday. Individual medical sessions may be scheduled between 8:00 and 9:00 a.m. and from 3:30 to 4:00, Monday through Friday. Attendance at one 12-step meeting per day is required during treatment.

Sample Evening IOT Program Schedule

For New Patients:
MON WED THU SAT | 5:30 - 7:30 5:30 - 7:30 4:30 - 7:30 8:30 - 10:30 | Lectures and therapy group Lecture and multifamily group Phase One group, lecture, and therapy group Activity therapy and living skills
Second Saturday of the month: Family Enrichment Day from 8:30 to 12:30.
For Family Members, Significant Others, Friends, and Support Persons:
MON WED SAT | 5:30 - 7:30 5:30 - 7:30 8:30 - 10:30 | Lecture and family group Lecture and multifamily group Activity therapy and living skills
Second Saturday of the month: Family Enrichment Day from 8:30 to 12:30.
For Phase Three Patients:
TUE WED THU | 5:45 - 7:15 9:30 - 11:00 am,and 5:45 - 7:15 pm THU 5:45 - 7:15
These patients meet one time per week. Persons completing Phase Two will choose any group that has available spaces. New groups will be formed as needed.
For Phase Three Members and All Former Patients:
Continuing Care Group: 6:00 - 7:30 This group is available, without charge, to all former patients of the program and can be used by members of Phase Three groups as additional structure during the week.

A fundamental aspect of the intensive evening outpatient treatment program is education about substance abuse. This occurs during the first half-hour of each evening session. Because the education program is designed to provide the essential information for building a strong personal program of recovery, it is essential that you come to each of the sessions and arrive on time. Although you may enter the program at any time, when you complete the eight weeks, you will have attended a complete sequence of lectures and will have heard several guest speakers. Normally, the lecture series consists of the following:

Lecture Schedule For Evening Program

Week One: | MON: | The Disease of Addiction/Disease Progression
Week One: | WED: | The Family Disease
Week One: | THU: | Guest speaker
Week Two: | MON: | Recovery is...
Week Two: | WED: | The Enabling Film
Week Two: | THU: | Recovery is...
Week Three: | MON: | Relapse Prevention Planning
Week Three: | WED: | Family Relapse
Week Three: | THU: | An Introduction to the 12 Steps of AA and NA
Week Four: | MON: | Medical Aspects of Addiction I
Week Four: | WED: | Alcohol and Opiates
Week Four: | THU: | Guest speaker
Week Five: | WED: | Medical Aspects of Addiction II
Week Five: | THU: | Marijuana and Hallucinogens
Week Five: | THU: | Cross-Addiction and Healthy Alternatives
Week Six: | MON: | Cocaine and Crack Addiction
Week Six: | WED: | Coffee, Cigarettes, Nutrition, and Recovery
Week Six: | THU: | Guest speaker
Week Seven: | MON: | The First Step: Surrender
Week Seven: | WED: | Sex and Relationships
Week Seven: | THU: | Spirituality
Week Eight: | MON: | Feelings and Addiction
Week Eight: | WED: | Anger
Week Eight: | THU: | Shame and Guilt