# Appendix A -- References

Alcohol, Drug Abuse, and Mental Health Administration. The Economic Costs of Alcohol and Drug Abuse and Mental Illness. Washington, D.C.: Alcohol, Drug Abuse, and Mental Health Administration. 1985.
Alfs, D.S., and McClellan, T.A. A day hospital program for dual diagnosis patients in a VA medical center. Hospital and Community Psychiatry. 1992;43(3):241-244. [pmid: 1313388].
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition. Washington, D.C.: American Psychiatric Association. 1984.
Beckman, L.J., and Amaro, H. Personal and social differences faced by women and men entering alcoholism treatment. Journal of Studies on Alcohol. 1986;47:135-146.
Bensinger, A., and Pilkington, C.F. An alternative method in the treatment of alcoholism: the United Technologies Corporation day treatment program. Journal of Occupational Medicine. 1983;25(4):300-303. [pmid: 6854419].
Blume, S.B. Women and alcohol: a review. . Journal of the American Medical Association. 1986;256:1467-1470.
Fink, E.B., Longabaugh, R., McCrady, B.M., Stout, R.L., Beattie, M., Ruggieri-Authelet, A., and McNeil, D. Effectiveness of alcoholism treatment in partial versus inpatient settings: twenty-four month outcomes. Addictive Behaviors. 1985;10:235-248.
Furst, C., Beckman, L., Nakamura, C., and Weiss, M. Utilization of Alcohol Treatment Services in California. Los Angeles: UCLA Alcohol Research Center Neuropsychiatric Institute. 1981.
Goodwin, D.W. Inpatient treatment of alcoholism: new life for the Minneapolis plan. New England Journal of Medicine. 1991;325:804-806.
Hayashida, M., Alterman, A.I., McLellan, A.T., O'Brien, C.P., Purtill, J.J., Volpicelli, J.R., Raphaelson, A.H., and Hall, C.P. Comparative effectiveness and costs of inpatient and outpatient detoxification of patients with mild-to-moderate alcohol withdrawal syndrome. . New England Journal of Medicine. 1989;320:358-365.
Hoffman, N.G., Halikas, J.A., Mee-Lee, D., and Weedman, D. Patient Placement Criteria for the Treatment of Psychoactive Substance Use Disorders. Washington, D.C.: The American Society of Addiction Medicine. 1991.
Hoffman, N.G., and Harrison, P.A. CATOR Report: Perspective on Admission and Outcome. St. Paul, Minnesota: Ramsey Clinic. 1988.
Hoffman, N.G., and Harrison, P.A. CATOR Report: Treatment Outcome—Adult Inpatients Two Years Later. St. Paul, Minnesota: Ramsey Clinic. 1988a.
Hoffman, N.G., and Miller, N.S. Psychiatric Annals. 1992.
Horn, J.L., and Wanberg, K.W. Alcoholism symptom patterns of men and women: a comparative study. Quarterly Journal of Studies on Alcoholism. 1970;31:40-51.
Hubbard, R.L. Drug Abuse Treatment: A National Study of Effectiveness. Chapel Hill: University of North Carolina Press. 1989.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. Washington, D.C.: National Academy Press. 1990.
Institute of Medicine. Treating Drug Problems: A Study of the Evolution, Effectiveness, and Financing of Public and Private Drug Treatment Services. Washington, D.C.: National Academy Press. 1990.
Joint Commission on Accreditation of Healthcare Organizations. Accreditation Manual for Mental Health, Chemical Dependency, and Mental Retardation/Developmental Disabilities Services. Oakbrook Terrace, Illinois: Joint Commission on Accreditation of Healthcare Organizations. 1993.
Kofoed, L., Kania, J., Walsh, T., and Atkinson, R.M. Outpatient treatment of patients with substance abuse and coexisting psychiatric disorders. American Journal of Psychiatry. 1986;143(7):867-872. [pmid: 3087222].
Leukefeld, C.G., Pickens, R.W., and Schuster, C.R. . Improving Drug Abuse Treatment. 1991.
Longabaugh, R., McCrady, B., Fink, E., Stout, R., McAuley, T., Doyle, C., and McNeill, D. Cost effectiveness of alcoholism treatment in partial versus inpatient settings: six-month outcomes. Journal of Studies on Alcohol. 1983;44:1049-1071.
McCaul, M.E., and Svikis, D.S. Improving Drug Abuse Treatment. 1991.
McLellan, A.T., Alterman, A.I., Cacciola, J., Metzger, D., and O'Brien, C.P. A new measure of substance abuse treatment: initial studies of the Treatment Services Review. Journal of Nervous and Mental Disease. 1992;180(2):101-110. [pmid: 1737971].
McLellan, A.T., Kushner, H., and Metzger, D. The fifth edition of the Addiction Severity Index. . Journal of Substance Abuse Treatment. 1992a;9(3):199-213. [pmid: 1334156].
McLellan, A.T., Luborsky, L., Cacciola, J., Griffith J., Evans, F., Barr H.L., and O'Brien, C.P. New data from the Addiction Severity Index: reliability and validity in three centers. . Journal of Nervous and Mental Disease. 1985;173:412-423.
McLellan, A.T., O'Brien, C.P., and Woody, G.E. An improved diagnostic evaluation instrument for substance abuse patients: the Addiction Severity Index. . Journal of Nervous and Mental Disease. 1980;168:26-33.
Price, R.H., Burke, A.C., D'Aunno, T.A., Klingel, D.M., McCaughrin, W.C., Rafferty, J.A., and Vaughn, T.E. Improving Drug Abuse Treatment. 1991.
Reed, B.G. Developing women-sensitive drug dependence treatment services: why so difficult?. Journal of Psychoactive Drugs. 1987;19:151-164.
Roman, P.M. Women and Alcohol Use: A Review of the Research Literature. Rockville, Maryland: Alcohol, Drug Abuse, and Mental Health Administration. 1988.
Scivoletto, S., Guerra de Andrade, AG., and Castel, S. The effect of a "recall-system" in the treatment of alcoholic patients. British Journal of Addiction. 1992;87:1185-1188.
Thom B. Sex differences in help-seeking for alcohol problems, 1: The barriers to help-seeking. British Journal of Addiction. 1986;81:777-788.
Unterberger, G. Christian Century. 1989.
Verinis, J.S. Characteristics of patients who continue with alcohol outpatient treatment. International Journal of the Addictions. 1986;21(1):25-31. [pmid: 3710639].
Walsh, D.C., Hingson, R.W., Merrigan, D.M., Levenson, S.M., Cupples, L.A., Heeren, T., Coffman, G.A., Becker, C.A., Barker, T.A., Hamilton, S.K., McGuire, T.G., and Kelly, C.A. A randomized trial of treatment options for alcohol-abusing workers. New England Journal of Medicine. 1991;325(11):775-782. [pmid: 1870651].
Walton, M. The Deming Management Method. New York: G.P. Putnam. 1990.
Washton, A.M. Recent Developments in Alcohol. 1990.
Weisner C., and Schmidt, L. Gender disparities in treatment for alcohol problems. Journal of the American Medical Association. 1992;268(14):1872-1876. [pmid: 1328695].
Yalom, I.D. The Theory and Practice of Group Psychotherapy, Third Edition. New York: Basic Books. 1985.