# Consensus Panel

Chair
- James A. Inciardi, Ph.D.
- Professor and Director
- Center for Drug and Alcohol Studies
- University of Delaware
- Newark, Delaware

Facilitators
- Marcia D. Andersen, Ph.D., R.N., F.A.A.N., C.S.
- President
- Personalized Nursing Corporation
- Plymouth, Michigan
- Duane C. McBride, Ph.D.
- Professor and Chair
- Behavioral Sciences Department
- Institute of Alcoholism and Drug Dependency
- Andrews University
- Berrien Springs, Michigan
- Harvey A. Siegal, Ph.D.
- Director
- Substance Abuse Intervention Programs
- Wright State University
- Dayton, Ohio
- William R. Williford, M.P.H., Ph.D.
- Deputy Director
- New York Office of Alcoholism and Substance Abuse Services
- Albany, New York

Workgroup Members
- Richard Asarian, Ph.D.
- Clinical Director
- Ielase Institute of Forensic Psychology
- Pittsburgh, Pennsylvania
- Virginia Blackburn
- Director
- Women's Alcohol and Drug Prevention
- Fort Wayne Women's Bureau
- Fort Wayne, Indiana
- LaClaire Green Bouknight, M.D., F.A.C.P.
- Medical Director
- Residential Care Division
- Michigan Department of Social Services
- Maxey Training School
- Whitmore Lake, Michigan
- Margaret K. Brooks, J.D.
- Consultant
- Montclair, New Jersey
- Leah Colette Clendening, R.N., M.P.A.
- Associate Executive Director
- Queens Hospital Center
- Jamaica, New York
- Preston A. Daniels, M.S.
- Director
- Central Assessment Center and Mid-City Programs
- National Council on Alcoholism and Other
- Drug Dependencies
- Des Moines, Iowa
- Zoila Torres Feldman, R.N., M.S.
- Executive Director
- Great Brook Valley Health Center
- Worcester, Massachusetts
- Michael L. Green, M.S.W.
- Chief Probation Officer
- Mercer County Probation Department
- Trenton, New Jersey
- Howard Isenberg, M.A.
- Project Director
- North East Treatment Centers
- Wilmington, Delaware
- Pamela F. Rodriguez, M.A.
- Director of Program Services
- Treatment Alternatives for Special Clients of Illinois
- Chicago, Illinois
- Gerald L. Vigdal, M.S.W., B.C.D.
- Director
- Office of Drug Programs
- Wisconsin Department of Corrections
- Madison, Wisconsin