# Appendix F—Field Reviewers

- Marcia D. Andersen, Ph.D., R.N., F.A.A.N., C.S.
- President
- Personalized Nursing Corporation
- Plymouth, Michigan

- Richard Asarian, Ph.D.
- Clinical Director
- Ielase Institute of Forensic Psychology
- Pittsburgh, Pennsylvania

- Catherine E. Bartels, M.Ed., C.C.D.C. III
- Director
- Substance Abuse Problems
- South Dakota Department of Corrections
- Pierre, South Dakota

- Virginia Blackburn
- Director
- Women's Alcohol and Drug Prevention
- Fort Wayne Women's Bureau
- Fort Wayne, Indiana

- LaClaire Green Bouknight, M.D., F.A.C.P.
- Medical Director
- Residential Care Division
- Michigan Department of Social Services
- Maxey Training School
- Whitmore Lake, Michigan

- Margaret K. Brooks, J.D.
- Consultant
- Montclair, New Jersey

- Leah Colette Clendening, R.N., M.P.A.
- Associate Executive Director
- Queens Hospital Center
- Jamaica, New York

- Preston A. Daniels, M.S.
- Director
- Central Assessment Center and Mid-City Programs
- National Council on Alcoholism and Other Drug Dependencies
- Des Moines, Iowa

- Sammye Davies
- Certified Alcohol and Drug Abuse Counselors
- Program Specialist
- Division on Alcoholism and Drug Abuse
- Nebraska Department of Public Institutions
- Lincoln, Nebrasla

- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida

- William L. Edelman, L.C.S.W., A.C.S.W.
- Division Manager
- Drug Abuse Services
- County of Orange
- Health Care Agency
- Santa Ana, California

- Gregory P. Falkin, Ph.D.
- Principal Investigator
- National Development and Research Institutes
- New York, New York

- Zoila Torres Feldman, R.N., M.S.
- Executive Director
- Great Brook Valley Health Center
- Worcester, Massachusetts

- Vernon A. Fogg
- Program Administrator
- Colorado Judicial Department
- Denver, Colorado

- Michael L. Green, M.S.W.
- Chief Probation Officer
- Mercer County Probation Department
- Trenton, New Jersey

- Bettye J. Harrison, M.S.W., L.I.S.W.
- Treatment Consultant
- South Carolina Commission on Alcohol and Drug Abuse
- Columbia, South Carolina

- Melody M. Heaps
- President
- Treatment Alternatives for Special Clients of Illinois
- Chicago, Illinois

- James A. Inciardi, Ph.D.
- Professor and Director
- Center for Drug and Alcohol Studies
- University of Delaware
- Newark, Delaware

- Howard Isenberg, M.A.
- Project Director
- North East Treatment Centers
- Wilmington, Delaware

- Genita Johnson, M.D., M.P.H.
- Project Director
- Catch the Hope Program
- Dimock Community Health Center
- Medford, Massachusetts

- Napoleon B. Johnson, III
- Director
- Correctional and Re-Entry Programs
- Phoenix House Foundation
- New York, New York

- James Kendrick, M.A., C.S.W., L.L.P.
- Clinical Coordinator
- Specialty Program Alcohol and Drug Abuse
- Substance Abuse Clinic
- Western Michigan University
- Kalamazoo, Michigan

- Keith J. Lang, M.S.W.
- Contract Administrator
- Bureau of Substance Abuse Services
- State of Wisconsin Department of Health and Social Services
- Madison, Wisconsin

- Allen R. "Pete" Martin
- Head
- DWI/Criminal Justice Branch
- Division of Mental Health, Developmental
- Disabilities, and Substance Abuse Services
- State Alcohol and Drug Section
- Raleigh, North Carolina

- Duane C. McBride, Ph.D.
- Professor and Chair
- Behavioral Sciences Department
- Institute of Alcoholism and Drug Dependency
- Andrews University
- Berrien Springs, Michigan

- Anlee D. Olson, B.A.
- Assistant Director
- Anne Arundel County Department of Health
- Open Door Substance Abuse Treatment Program
- Annapolis, Maryland

- Roger H. Peters, Ph.D.
- Assistant Professor
- Department of Law and Mental Health
- Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- Marilyn McCoy Roberts
- Deputy Director
- National Center for State Courts
- Arlington, Virginia

- Pamela F. Rodriguez, M.A.
- Director of Program Services
- Treatment Alternatives for Special Clients of Illinois
- Chicago, Illinois

- Debra Royce, A.C.S.W.
- Director
- Phoenix House Marcy I Project
- Marcy Correctional Facility
- Marcy, New York

- Harvey A. Siegal, Ph.D.
- Director
- Substance Abuse Intervention Programs
- Wright State University
- Dayton, Ohio

- Richard Speiglman, D.Crim.
- Research Scientist
- The Marin Institute for the Prevention of Alcohol and Other Drug Problems
- San Rafael, California

- David S. Timken, Ph.D.
- Research Scientist and Clinical Consultant
- Alcohol and Drug Abuse Division
- Colorado Department of Health
- Denver, Colorado

- Gerald L. Vigdal, M.S.W., B.C.D.
- Director
- Office of Drug Programs
- Wisconsin Department of Corrections
- Madison, Wisconsin

- Cheryl Clark Walker
- Program Specialist
- Substance Abuse Program Section
- Michigan Department of Corrections
- Lansing, Michigan

- Harry K. Wexler, Ph.D.
- Principal Investigator
- Center for Therapeutic Community Research
- Laguna Beach, California

- William R. Williford, M.P.H., Ph.D.
- Deputy Director
- Office of Alcoholism and Substance Abuse Services
- Albany, New York