# Appendix B—CSAT Criminal Justice Treatment Planning

The Criminal Justice Treatment Planning Chart is a 3 1/2 foot fold-out chart suitable for display. The reverse side of the chart contains a glossary of the terms used in the chart. There was no effective way to present this chart in electronic format.

A copy of the entire TIP containing the chart can be ordered from the National Clearinghouse of Drug and Alcohol Information (NCADI). The order number for TIP 7: Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System is BKD138. It is free and can be ordered from NCADI's electronic catalog at http://www.health.org/pubs/catalog/ordering.htm or by calling 1-800-729-6686.