# Appendix A—References and Bibliography

## References Cited

Collins, J., and Allison, M. Legal coercion and retention in drug abuse treatment. Hospital and Community Psychiatry. 1983;34(12):1145-1149. [pmid: 6642461].
De Leon G., and Jainchill, N. Circumstances, Circumstance, motivation, readiness and suitability as correlates of treatment tenure. Journal of Psychoactive Drugs. 1986;18(3):203-208. [pmid: 3772644].
Gorski, T.G.Addiction and Recovery1991
Inciardi, J.A.TIE Communique1993
Leukefeld, C.G., and Tims, F.M., eds. Compulsory Treatment of Drug Abuse: Research and Clinical Practice. Rockville, MD: National Institute on Drug Abuse. 1988.

## Bibliography

Allen, J.P., Eckart, Eckardt, M.J., and Wallen, J. Screening for alcoholism: techniques and issues. Public Health Reports. 1988;103(6):586-592. [pmid: 3141951].
Meijer, L. Developing a substance abuse assessment: avoiding the pitfalls. Perspectives. 1990;Fall:12-14.
Rounsaville, B. Clinical assessment of drug abusers. In: Treatments of Psychiatric Disorders. Washington, DC: American Psychiatric Association, 1989. pp. 1183-1192.
Shaffer, H.J. The psychology of stage change: the transition from addiction to recovery. In: Lowinson, J.H., Ruiz, P., Millman, R.B., and Langrod, J.G., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams and Wilkins, 1992. pp. 100-105.
Singer, A. Effective treatment for drug-involved offenders: a review and synthesis for judges and other court personnel. Newton, Massachusetts: Education Development Center, 1992. pp. 86-103.
Vigdal, G. Summary of uniform substance abuse screening battery: Wisconsin Department of Corrections. In: Drug Offender Assessment Monograph. Washington, DC: National Association of State Alcohol and Drug Abuse Directors, 1991. pp. 349-351.
Vigdal, G.L., and Stadler, D.W. Comprehensive system development in corrections for drug-abusing offenders: the Wisconsin Department of Corrections. Drug Abuse Treatment in Prisons and Jails. NIDA Research Monograph Series 118:126-141. 1992.