# General Bibliography

aan het Rot M, Hogenelst K, Schoevers RA. Mood disorders in everyday life: A systematic review of experience sampling and ecological momentary assessment studies. Clinical Psychology Review. 2012;32:510-523. [pmid: 22721999].
Abbass A, Arthey S, Elliott J, Fedak T, Nowoweiski D, Markovski J, Nowoweiski S. Web-conference supervision for advanced psychotherapy training: A practical guide. Psychotherapy: Theory, Research, Practice, Training. 2011;48:109-118.
Abbate DG, Gramaglia C, Piero A, Fassino S. Eating disorders and the Internet: Cure and curse. Eating and Weight Disorders. 2006;11:e68-e71. [pmid: 16809973].
Abbott JA, Klein B, Ciechomski L. Best practices in online therapy. Journal of Technology in Human Services. 2008;26:360-375.
Abney PC, Maddux CD. Counseling and technology: Some thoughts about the controversy. Journal of Technology in Human Services. 2004;22:1-24.
Abroms LC, Gill J, Windsor R, Simons-Morton B. A process evaluation of e-mail counselling for smoking cessation in college students: Feasibility, acceptability and cost. Journal of Smoking Cessation. 2009;4:26-33.
Abroms LC, Padmanabhan N, Thaweethai L, Phillips T. iPhone apps for smoking cessation: A content analysis. American Journal of Preventive Medicine. 2011;40:279-285. [pmid: 21335258].
Acosta MC, Marsch LA, Xie H, Guarino H, Aponte-Melendez Y. A Web-based behavior therapy program influences the association between cognitive functioning and retention and abstinence in clients receiving methadone maintenance treatment. Journal of Dual Diagnosis. 2012;8:283-293. [pmid: 23671409].
Agha Z, Roter DL, Schapira RM. An evaluation of patient-physician communication style during telemedicine consultations. Journal of Medical Internet Research. 2009;11:e36. [pmid: 19793720].
Agrawal V. Podcasts for psychiatrists: A new way of learning. Psychiatric Bulletin. 2007;31:270-271.
Aguilera A, Muñoz RF. Text messaging as an adjunct to CBT in low-income populations: A usability and feasibility pilot study. Professional Psychology: Research and Practice. 2011;42:472-478.
Ainsworth M. My life as an e-patient. Hsiung RC, editor. E-therapy: Case studies, guiding principles, and the clinical potential of the Internet. 2002:194-215. New York. W. W. Norton & Co.
Alcañiz M, Botella C, Baños R, Perpiñá C, Rey B, Lozano JA, Gil JA. Internet-based telehealth system for the treatment of agoraphobia. CyberPsychology & Behavior. 2003;6:355-358. [pmid: 14511446].
Alcañiz M, Botella C, Baños RM, Zaragoza I, Guixeres J. The intelligent e-therapy system: A new paradigm for telepsychology and cybertherapy. British Journal of Guidance & Counselling. 2009;37:287-296.
Alcañiz M, Lozano JA, Rey B. Technological background about VR. Riva G, Botella C, Legeron P, Optale G, editors. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:199-216. Amsterdam. Ios Press.
Alemi F, Haack MR, Harge A, Dill R, Benson L. Engaging client's family and friends in online counseling. Journal of Addictions Nursing. 2005;16:47-55. [pmid: 19997537].
Alemi F, Haack MR, Nemes S, Aughburns R, Sinkule J, Neuhauser D. Therapeutic emails. Substance Abuse Treatment, Prevention, and Policy. 2007;2:7.
Alleman JR. Online counseling: The Internet and mental health treatment. Psychotherapy: Theory, Research, Practice, Training. 2002;39:199-209.
Almlov J, Carlbring P, Berger T, Cuijpers P, Andersson G. Therapist factors in Internet-delivered cognitive behavioural therapy for major depressive disorder. Cognitive Behaviour Therapy. 2009;38:247-254. [pmid: 19802751].
Almlov J, Carlbring P, Kallqvist K, Paxling B, Cuijpers P, Andersson G. Therapist effects in guided Internet-delivered CBT for anxiety disorders. Behavioural and Cognitive Psychotherapy. 2011;39:311-322. [pmid: 21144121].
Amarendran V, George A, Gersappe V, Krishnaswamy S, Warren C. The reliability of telepsychiatry for a neuropsychiatric assessment. Telemedicine and eHealth. 2011;17:223-225.
American Telemedicine Association. 2012. New generation of virtual humans helping to train psychologists. Washington DC. Author.
American Telemedicine Association. 2009. Evidence-based practice for telemental health. Washington DC. Author.
American Telemedicine Association. 2010. Category: US states. Washington DC. Author.
Amig S. Internet dilemmas (HIPAA, on-line counseling raise serious issues). Behavioral Health Management. 2001;21:48-51.
Amir N, Beard C, Burns M, Bomyea J. Attention modification program in individuals with generalized anxiety disorder. Journal of Abnormal Psychology. 2009;118:28-33. [pmid: 19222311].
Amir N, Beard C, Taylor CT, Klumpp H, Elias J, Burns M, Chen X. Attention training in individuals with generalized social phobia: A randomized controlled trial. Journal of Consulting and Clinical Psychology. 2009;77:961-973. [pmid: 19803575].
Amir N, Weber G, Beard C, Bomyea J, Taylor CT. The effect of a single-session attention modification program on response to a public-speaking challenge in socially anxious individuals. Journal of Abnormal Psychology. 2008;117:860-868. [pmid: 19025232].
Amstadter AB, Broman-Fulks J, Zinzow H, Ruggiero KJ, Cercone J. Internet-based interventions for traumatic stress–related mental health problems: A review and suggestion for future research. Clinical Psychology Review. 2009;29:410-420. [pmid: 19403215].
An LC, Klatt C, Perry CL, Lein EB, Hennrikus DJ, Pallonen UE, Ehlinger EP. The RealU online cessation intervention for college smokers: A randomized controlled trial. Preventive Medicine. 2008;47:194-199. [pmid: 18565577].
An LC, Schillo BA, Saul JE, Wendling AH, Klatt CM, Berg CJ, Luxenberg MG. Utilization of smoking cessation informational, interactive, and online community resources as predictors of abstinence: Cohort study. Journal of Medical Internet Research. 2008;10:e55. [pmid: 19103587].
Andersson G. Internet-based cognitive–behavioral self help for depression. Expert Review of Neurotherapeutics. 2006;6:1637-1642. [pmid: 17144778].
Andersson G. Using the Internet to provide cognitive behaviour therapy. Behaviour Research and Therapy. 2009;47:175-180. [pmid: 19230862].
Andersson G, Bergstrom J, Buhrman M, Carlbring P, Holländare F, Kaldo V, Waara J. Development of a new approach to guided self-help via the Internet: The Swedish experience. Journal of Technology in Human Services. 2008;26:161-181.
Andersson G, Bergstrom J, Carlbring P, Lindefors N. The use of the Internet in the treatment of anxiety disorders. Current Opinion in Psychiatry. 2005;18.
Andersson G, Bergstrom J, Holländare F, Carlbring P, Kaldo V, Ekselius L. Internet-based self-help for depression: Randomised controlled trial. British Journal of Psychiatry. 2005;187:456-461. [pmid: 16260822].
Andersson G, Carlbring P. Internet and cognitive behaviour therapy: New opportunities for treatment and assessment. Cognitive Behaviour Therapy. 2003;32:97-99. [pmid: 16291541].
Andersson G, Carlbring P. Commentary on Berger, Hohl, and Caspar's (2009) Internet-based treatment for social phobia: A randomized controlled trial. Journal of Clinical Psychology. 2009;65:1036-1038. [pmid: 19688814].
Andersson G, Carlbring P, Berger T, Almlov J, Cuijpers P. What makes Internet therapy work?. Cognitive Behaviour Therapy. 2009;1.
Andersson G, Carlbring P, Grimlund A. Predicting treatment outcome in Internet versus face to face treatment of panic disorder. Computers in Human Behavior. 2008;24:1790-1801.
Andersson G, Carlbring P, Holmstrom A, Sparthan E, Furmark T, Nilsson-Ihrfelt E, Ekselius L. Internet-based self-help with therapist feedback and in vivo group exposure for social phobia: A randomized controlled trial. Journal of Consulting and Clinical Psychology. 2006;74:677-686. [pmid: 16881775].
Andersson G, Carlbring P, Kaldo V, Strom L. Screening of psychiatric disorders via the Internet. A pilot study with tinnitus patients. Nordic Journal of Psychiatry. 2004;58:287-291. [pmid: 15370777].
Andersson G, Cuijpers P. Internet-based and other computerized psychological treatments for adult depression: A meta-analysis. Cognitive Behaviour Therapy. 2009;38:196-205. [pmid: 20183695].
Andersson G, Kaldo V. Internet-based cognitive behavioral therapy for tinnitus. Journal of Clinical Psychology. 2004;60:171-178. [pmid: 14724924].
Andersson G, Lundstrom P, Strom L. Internet-based treatment of headache: Does telephone contact add anything?. Headache. 2003;43:353-361. [pmid: 12656706].
Andersson G, Stromgren T, Strom L, Lyttkens L. Randomized controlled trial of Internet-based cognitive behavior therapy for distress associated with tinnitus. Psychosomatic Medicine. 2002;64:810-816. [pmid: 12271112].
Andersson G, Waara J, Jonsson U, Malmaeus F, Carlbring P, Ost LG. Internet-based self-help versus one-session exposure in the treatment of spider phobia: A randomized controlled trial. Cognitive Behaviour Therapy. 2009;38:114-120. [pmid: 20183690].
Andre B, Ringdal GI, Loge JH, Rannestad T, Kaasa S. The importance of key personnel and active management for successful implementation of computer-based technology in palliative care: Results from a qualitative study. Computers Informatics Nursing. 2008;26:183-189.
Andrews G, Cuijpers P, Craske MG, McEvoy P, Titov N. Computer therapy for the anxiety and depressive disorders is effective, acceptable and practical health care: A meta-analysis. PLOS One. 2010;5:e13196. [pmid: 20967242].
Andrews G, Davies M, Titov N. Effectiveness randomized controlled trial of face to face versus Internet cognitive behaviour therapy for social phobia. Australian and New Zealand Journal of Psychiatry. 2011;45:337-340. [pmid: 21323490].
Andrews G, Titov N. Is Internet treatment for depressive and anxiety disorders ready for prime time?. Medical Journal of Australia. 2010;192:S45-S47. [pmid: 20528709].
Anthony K. 2004. Therapy online—The therapeutic relationship in typed text. Bolton G, Howlett S, Lago C, Wright JK, editors. Writing cures: An introductory handbook of writing in counselling and psychotherapy. Hove, United Kingdom. Brunner–Routledge.
Anthony K. Counselling problem gamblers online. BACP Counselling and Psychotherapy Journal. 2005;16:9-10.
Anthony K, Nagel DM, Goss S. 2010. The use of technology in mental health: Applications, ethics and practice. Springfield, IL. Charles C. Thomas Publisher.
Antonacci DJ, Bloch RM, Sy AS, Yildirim Y, Talley J. Empirical evidence on the use and effectiveness of telepsychiatry via videoconferencing: Implications for forensic and correctional psychiatry. Behavioral Sciences & the Law. 2008;26:253-269. [pmid: 18548519].
APA Practice Organization. 2011. Reimbursement for telehealth services. Washington DC. Author.
Apostolides M. Drug-related sites on the world wide Web. International Journal of Drug Policy. 1995;6:228-233.
Araya RI, Wynn R, Lewis G. Comparison of two self administered psychiatric questionnaires (GHQ-12 and SRQ-20) in primary care in Chile. Social Psychiatry and Psychiatric Epidemiology. 1992;27:168-173. [pmid: 1411744].
Armfield NR, Gray LC, Smith AC. Clinical use of Skype: A review of the evidence base. Journal of Telemedicine and Telecare. 2012;18:125-127. [pmid: 22362829].
Aronson ID, Plass JL, Bania TC. Optimizing educational video through comparative trials in clinical environments. Educational Technology Research and Development. 2012;60:469-482. [pmid: 22904607].
Arrieta MI, Foreman RD, Crook ED, Icenogle ML. Providing continuity of care for chronic diseases in the aftermath of Katrina: From field experience to policy recommendations. Disaster Medicine and Public Health Preparedness. 2009;3:174-182. [pmid: 19865042].
Aten JD, Leavell K, Gonzalez R, Luke T, Defee J, Harrison K. Everyday technologies for extraordinary circumstances: Possibilities for enhancing disaster communication. Psychological trauma: Theory, research, practice, and policy. 2011;3:16-20.
Atherton H, Sawmynaden P, Sheikh A, Majeed A, Car J. Email for clinical communication between patients/caregivers and healthcare professionals. Cochrane Database of Systematic Reviews. 2012;11. CD007978.
Atkinson NL, Gold RS. The promise and challenge of eHealth interventions. American Journal of Health Behavior. 2002;26:494-503. [pmid: 12437024].
Atkinson S, Ayers A. The potential of the Internet for alternative caring practices for health. Anthropology & Medicine. 2010;17:75-86. [pmid: 20419518].
Aukstakalnis S, Blattner D. 1992. Silicon mirage: The art and science of virtual reality. Berkeley, CA. Peachpit Press.
Austen S, McGrath M. Telemental health technology in deaf and general mental-health services: Access and use. American Annals of the Deaf. 2006;151:311-317. [pmid: 17087441].
Aydos L, Titov N, Andrews G. Shyness 5: The clinical effectiveness of Internet-based clinician-assisted treatment of social phobia. Australasian Psychiatry. 2009;17:488-492. [pmid: 20001373].
Bachofen M, Nakagawa A, Marks IM, Park JM, Greist JH, Baer L, Dottl SL. Home self-assessment and self-treatment on obsessive–compulsive disorder using a manual and a computer-conducted telephone interview: Replication of a US–UK study. Journal of Clinical Psychiatry. 1999;60:545-549. [pmid: 10485637].
Backhaus A, Agha Z, Maglione ML, Repp A, Ross B, Zuest D, Thorp SR. Videoconferencing psychotherapy: A systematic review. Psychological Services. 2012;9:111-131. [pmid: 22662727].
Bader SA, Braude RM. “Patient informatics”: Creating new partnerships in medical decision making. Academic Medicine. 1998;73:408-411. [pmid: 9580718].
Baggett KM, Davis B, Feil EG, Sheeber LL, Landry SH, Carta JJ, Leve C. Technologies for expanding the reach of evidence-based interventions: Preliminary results for promoting social–emotional development in early childhood. Topics in Early Childhood Special Education. 2010;29:226-238. [pmid: 20454545].
Bai YM, Lin CC, Chen JY. Internet addiction disorder among clients of a virtual clinic. Psychiatric Services. 2001;52:1397. [pmid: 11585966].
Bai YM, Lin CC, Chen JY, Liu WC. Virtual psychiatric clinics. American Journal of Psychiatry. 2001;158:1160-1161. [pmid: 11431247].
Baker DC, Bufka LF. Preparing for the telehealth world: Navigating legal, regulatory, reimbursement, and ethical issues in an electronic age. Professional Psychology: Research and Practice. 2011;42:405-411.
Baker JR, Moore SM. Distress, coping, and blogging: Comparing new Myspace users by their intention to blog. CyberPsychology & Behavior. 2008;11:81-85. [pmid: 18275317].
Bakke B, Mitchell J, Wonderlich S, Erickson R. Administering cognitive–behavioral therapy for bulimia nervosa via telemedicine in rural settings. International Journal of Eating Disorders. 2001;30:454-457. [pmid: 11746307].
Balachandra K. Re: The Internet's impact on the practice of psychiatry: Comment. The Canadian Journal of Psychiatry/La Revue Canadienne de Psychiatrie. 2004;49:868.
Balmford J, Borland R, Benda P. Patterns of use of an automated interactive personalized coaching program for smoking cessation. Journal of Medical Internet Research. 2008;10:e54. [pmid: 19097975].
Balmford J, Borland R, Li L, Ferretter I. Usage of an Internet smoking cessation resource: The Australian QuitCoach. Drug and Alcohol Review. 2009;28:66-72. [pmid: 19320678].
Baloglu M, Çevik V. Multivariate effects of gender, ownership, and the frequency of use on computer anxiety among high school students. Computers in Human Behavior. 2008;24:2639-2648.
Baltimore ML. Ethical considerations in the use of technology for marriage and family counselors. The Family Journal. 2000;8:390-393.
Bambling M, King R, Reid W, Wegner K. Online counselling: The experience of counsellors providing synchronous single-session counselling to young people. Counselling & Psychotherapy Research. 2008;8:110-116.
Baños RM, Guillen V, Quero S, Garcia-Palacios A, Alcañiz M, Botella C. A virtual reality system for the treatment of stress-related disorders: A preliminary analysis of efficacy compared to a standard cognitive behavioral program. International Journal of Human Computer Studies. 2011;69:602-613.
Barak A. Psychological applications on the Internet: A discipline on the threshold of a new millennium. Applied & Preventive Psychology. 1999;8:231-245.
Barak A. Emotional support and suicide prevention through the Internet: A field project report. Computers in Human Behavior. 2007;23:971-984.
Barak A, Bloch N. Factors related to perceived helpfulness in supporting highly distressed individuals through an online support chat. CyberPsychology & Behavior. 2006;9:60-68. [pmid: 16497119].
Barak A, Buchanan T. Internet-based psychological testing and assessment. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:217-239. New York. Elsevier Science.
Barak A, Boneh O, Dolev-Cohen M. Factors underlying participants' gains in online support groups. Blachnio AE, Przepiórka AE, Rowin'ski T, editors. Internet in psychological research. 2010:17-38. Warsaw, Poland. Cardinal Stefan Wyszyński University Press.
Barak A, Boniel-Nissim M, Suler J. Fostering empowerment in online support groups. Computers in Human Behavior. 2008;24:1867-1883.
Barak A, Hen L, Boniel-Nissim M, Shapira N. A comprehensive review and a meta-analysis of the effectiveness of Internet-based psychotherapeutic interventions. Journal of Technology in Human Services. 2008;26:109-160.
Barak A, Klein B, Proudfoot JG. Defining Internet-supported therapeutic interventions. Annals of Behavioral Medicine. 2009;38:4-17. [pmid: 19787305].
Barak A, Wander-Schwartz M. Empirical evaluation of brief group therapy conducted in an Internet chat room. Journal of Virtual Environments. 2000;5(1).
Barlow JH, Ellard DR, Hainsworth JM, Jones FR, Fisher A. A review of self-management interventions for panic disorders, phobias and obsessive–compulsive disorders. Acta Psychiatrica Scandinavica. 2005;111:272-285. [pmid: 15740463].
Barnes C, Harvey R, Mitchell P, Smith M, Wilhelm K. Evaluation of an online relapse prevention program for bipolar disorder: An overview of the aims and methodology of a randomized controlled trial. Disease Management & Health Outcomes. 2007;15:215-224.
Barnett JE. Online counseling: New entity, new challenges. Counseling Psychologist. 2005;33:872-880.
Barnett JE. Utilizing technological innovations to enhance psychotherapy supervision, training, and outcomes. Psychotherapy. 2011;48:103-108. [pmid: 21639653].
Barnett JE, Scheetz K. Technological advances and telehealth: Ethics, law, and the practice of psychotherapy. Psychotherapy: Theory, Research, Practice, Training. 2003;40:86-93.
Barnett NP, Tidey J, Murphy JG, Swift R, Colby SM. Contingency management for alcohol use reduction: A pilot study using a transdermal alcohol sensor. Drug and Alcohol Dependence. 2011;118:391-399. [pmid: 21665385].
Barnwell SV, Juretic MA, Hoerster KD, Van de Plasch R, Felker BL. VA Puget Sound telemental health service to rural veterans: A growing program. Psychological Services. 2012;9:209-211. [pmid: 22662737].
Barrera AZ, Perez-Stable EJ, Delucchi KL, Muñoz RF. Global reach of an Internet smoking cessation intervention among Spanish- and English-speaking smokers from 157 countries. International Journal of Environmental Research and Public Health. 2009;6:927-940. [pmid: 19440423].
Barretto AI, Bingham CR, Goh KN, Shope JT. Developing a Web-based health promotion intervention: A case study from a brief motivational alcohol program. Health Promotion Practice. 2011;12:193-201. [pmid: 21051327].
Barry DT. Assessing culture via the Internet: Methods and techniques for psychological research. Cyberpsychology & Behavior. 2001;4:17-21. [pmid: 11709905].
Bass SB. How will Internet use affect the patient? A review of computer network and closed Internet-based system studies and the implications in understanding how the use of the Internet affects patient populations. Journal of Health Psychology. 2003;8:25-38. [pmid: 22113898].
Bauer S, Moessner M, Wolf M, Haug S, Kordy H. ES[S]PRIT: An Internet-based programme for the prevention and early intervention of eating disorders in college students. British Journal of Guidance & Counselling. 2009;37:327-336.
Bauer S, Percevic R, Okon E, Meermann R, Kordy H. Use of text messaging in the aftercare of patients with bulimia nervosa. European Eating Disorders Review. 2003;11:279-290.
Bauer S, Wolf M, Haug S, Kordy H. The effectiveness of Internet chat groups in relapse prevention after inpatient psychotherapy. Psychotherapy Research. 2011;21:219-226. [pmid: 21347978].
Baur C. Limiting factors on the transformative powers of e-mail in patient-physician relationships: A critical analysis. Health Communication. 2000;12:239-259. [pmid: 10938915].
Beard C, Weisberg RB, Amir N. Combined cognitive bias modification treatment for social anxiety disorder: A pilot trial. Depression and Anxiety. 2011;28:981-988. [pmid: 21898705].
Becker J, Fliege H, Kocalevent RD, Bjorner JB, Rose M, Walter OB, Klapp BF. Functioning and validity of a Computerized Adaptive Test to measure anxiety (A-CAT). Depression and Anxiety. 2008;25:E182-E194. [pmid: 18979458].
Beckner V, Howard I, Vella L, Mohr DC. Telephone-administered psychotherapy for depression in MS patients: Moderating role of social support. Journal of Behavioral Medicine. 2010;33:47-59. [pmid: 19941048].
Beebe TJ, Harrison PA, Park E, McRae J, Evans J. The effects of data collection mode and disclosure on adolescent reporting of health behavior. Social Science Computer Review. 2006;24:476-488.
Beidas RS, Koerner K, Weingardt KR, Kendall PC. Training research: Practical recommendations for maximum impact. Administration and Policy in Mental Health and Mental Health Services Research. 2011;38(4):223-237. [pmid: 21380792].
Bell V, Maiden C, Muñoz-Solomando A, Reddy V. ‘Mind control’ experiences on the Internet: Implications for the psychiatric diagnosis of delusions. Psychopathology. 2006;39:87-91. [pmid: 16391510].
Bellafiore DR, Colon Y, Rosenberg P. Online counseling groups. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:197-216. New York. Elsevier Science.
Bendtsen P, Timpka T. Acceptability of computerized self-report of alcohol habits: A patient perspective. Alcohol and Alcoholism. 1999;34:575-580. [pmid: 10456586].
Bendtsen P, Holmqvist M, Johansson K. Implementation of computerized alcohol screening and advice in an emergency department—A nursing staff perspective. Accident and Emergency Nursing. 2007;15:3-9. [pmid: 17113773].
Bendtsen P, Johansson K, Akerlind I. Feasibility of an email-based electronic screening and brief intervention (e-SBI) to college students in Sweden. Addictive Behaviors. 2006;31:777-787. [pmid: 15996827].
Bennett GG, Glasgow RE. The delivery of public health interventions via the Internet: Actualizing their potential. Annual Review of Public Health. 2009;30:273-292.
Bennett K, Bennett AJ, Griffiths KM. Security considerations for e-mental health interventions. Journal of Medical Internet Research. 2010;12:e61. [pmid: 21169173].
Bennett K, Reynolds J, Christensen H, Griffiths KM. E-hub: An online self-help mental health service in the community. Medical Journal of Australia. 2010;192:S48-S52. [pmid: 20528710].
Ben-Zeev D, Brenner CJ, Begale M, Duffecy J, Mohr DC, Mueser KT. Feasibility, acceptability, and preliminary efficacy of a smartphone intervention for schizophrenia. Schizophrenia Bulletin. 2014;40(6):1244-1253. [pmid: 24609454].
Ben-Zeev D, McHugo GJ, Xie H, Dobbins K, Young MA. Comparing retrospective reports to real-time/real-place mobile assessment in individuals with schizophrenia and a nonclinical comparison group. Schizophrenia Bulletin. 2012;38:396-404. [pmid: 22302902].
Berendsen AJ, de Jong GM, Schuling J, Bosveld HE, de Waal MW, Mitchell GK, Meyboom-de Jong B. Patient's need for choice and information across the interface between primary and secondary care: A survey. Patient Education and Counseling. 2010;79:100-105. [pmid: 19713065].
Berger T. Computer-based technological applications in psychotherapy training. Journal of Clinical Psychology. 2004;60:301-315. [pmid: 14981793].
Berger T, Caspar F, Richardson R, Kneubuler B, Sutter D, Andersson G. Internet-based treatment of social phobia: A randomized controlled trial comparing unguided with two types of guided self-help. Behaviour Research and Therapy. 2011;49:158-169. [pmid: 21255767].
Berger T, Hammerli K, Gubser N, Andersson G, Caspar F. Internet-based treatment of depression: A randomized controlled trial comparing guided with unguided self-help. Cognitive Behaviour Therapy. 2011;40:251-266. [pmid: 22060248].
Berger T, Hohl E, Caspar F. Internet-based treatment for social phobia: A randomized controlled trial. Journal of Clinical Psychology. 2009;65:1021-1035. [pmid: 19437505].
Bergman DA, Beck A, Rahm AK. The use of Internet-based technology to tailor well-child care encounters. Pediatrics. 2009;124:e37-e43. [pmid: 19564267].
Bergquist TF, Thompson K, Gehl C, Muñoz PJ. Satisfaction ratings after receiving Internet-based cognitive rehabilitation in persons with memory impairments after severe acquired brain injury. Telemedicine Journal and e-Health. 2010;16:417-423. [pmid: 20420542].
Bergquist T, Gehl C, Lepore S, Holzworth N, Beaulieu W. Internet based cognitive rehabilitation in individuals with acquired brain injury: A pilot feasibility study. Brain Injury. 2008;22:891-897. [pmid: 18850347].
Bergquist T, Gehl C, Mandrekar J, Lepore S, Hanna S, Osten A, Beaulieu W. The effect of Internet-based cognitive rehabilitation in persons with memory impairments after severe traumatic brain injury. Brain Injury. 2009;23:790-799. [pmid: 19697167].
Bergstrom J, Andersson G, Karlsson A, Andreewitch S, Ruck C, Carlbring P, Lindefors N. An open study of the effectiveness of Internet treatment for panic disorder delivered in a psychiatric setting. Nordic Journal of Psychiatry. 2009;63:44-50. [pmid: 18985514].
Berman RL, Iris MA, Bode R, Drengenberg C. The effectiveness of an online mind-body intervention for older adults with chronic pain. The Journal of Pain. 2009;10:68-79. [pmid: 18774342].
Bersamin M, Paschall MJ, Fearnow-Kenney M, Wyrick D. Effectiveness of a Web-based alcohol-misuse and harm-prevention course among high- and low-risk students. Journal of American College Health. 2007;55:247-254. [pmid: 17319331].
Bessell TL, McDonald S, Silagy CA, Anderson JN, Hiller JE, Sansom LN. Do Internet interventions for consumers cause more harm than good? A systematic review. Health Expectations. 2002;5:28-37. [pmid: 11906539].
Bewick BM, Trusler K, Barkham M, Hill AJ, Cahill J, Mulhern B. The effectiveness of Web-based interventions designed to decrease alcohol consumption—A systematic review. Preventive Medicine. 2008;47:17-26. [pmid: 18302970].
Bewick BM, Trusler K, Mulhern B, Barkham M, Hill AJ. The feasibility and effectiveness of a Web-based personalised feedback and social norms alcohol intervention in UK university students: A randomised control trial. Addictive Behaviors. 2008;33:1192-1198. [pmid: 18554819].
Bickel WK, Christensen DR, Marsch LA. A review of computer-based interventions used in the assessment, treatment, and research of drug addiction. Substance Use & Misuse. 2011;46:4-9. [pmid: 21190401].
Bickel WK, Marsch LA. A future for the prevention and treatment of drug abuse: Applications of computer-based interactive technology. Henningfield JE, Santora PB, Bickel WK, editors. Addiction treatment: Science and policy for the twenty-first century. 2007:35-43. Baltimore. Johns Hopkins University Press.
Bickel WK, Marsch LA, Budney AJ. Technology-delivered treatments for substance use disorders: Current status and future directions. Miller PM, editor. Encyclopedia of Addictive Behaviors. 2012;3:275-286. New York. Elsevier Limited.
Bickel WK, Marsch LA, Buchhalter AR, Badger GJ. Computerized behavior therapy for opioid-dependent outpatients: A randomized controlled trial. Experimental and Clinical Psychopharmacology. 2008;16:132-143. [pmid: 18489017].
Bickmore T, Gruber A. Relational agents in clinical psychiatry. Harvard Review of Psychiatry. 2010;18:119-130. [pmid: 20235777].
Bickmore T, Gruber A, Picard R. Establishing the computer-patient working alliance in automated health behavior change interventions. Patient Education and Counseling. 2005;59:21-30. [pmid: 16198215].
Billings G. 2012. Michigan becomes 15th state to pass private payer telehealth reimbursement. Washington DC. Center for Telehealth and e-Health Law.
Bird J. “I wish to speak to the despisers of the body”: The Internet, physicality, and psychoanalysis. Journal for the Psychoanalysis of Culture & Society. 2003;8:121-126.
Birgegard A, Bjorck C, Clinton D. Quality assurance of specialised treatment of eating disorders using large-scale Internet-based collection systems: Methods, results and lessons learned from designing the Stepwise database. European Eating Disorders Review. 2010;18:251-259. [pmid: 20589767].
Bischof RJ. The megs and I; CD practice on-line. Behavioral Health Management. 1994;14:14.
Bischof RJ. Considerations in the use of telecommunications as a primary treatment medium: The application of behavioral telehealth to marriage and family therapy. American Journal of Family Therapy. 2004;32:173-187.
Bishop D, Bryant KS, Giles SM, Hansen WB, Dusenbury L. Simplifying the delivery of a prevention program with Web-based enhancements. The Journal of Primary Prevention. 2006;27:433-444. [pmid: 16763766].
Bland PH, Laderach GE, Meyer CR. A Web-based interface for communication of data between the clinical and research environments without revealing identifying information. Academic Radiology. 2007;14:757-764. [pmid: 17502264].
Blankers M, Koeter MWJ, Schippers GM. Internet therapy versus Internet self-help versus no treatment for problematic alcohol use: A randomized controlled trial. Journal of Consulting and Clinical Psychology. 2011;79:330-341. [pmid: 21534652].
Bledsoe TS, Simmerok BD. A multimedia-rich platform to enhance student engagement and learning in an online environment. Journal of Asynchronous Learning Networks. 2014;17(4):57-66.
Block G, Sternfeld B, Block HC, Block JT, Norris J, Hopkins D, Clancy HA. Development of Alive! (A Lifestyle Intervention Via Email), and its effect on health-related quality of life, presenteeism, and other behavioral outcomes: Randomized controlled trial. Journal of Medical Internet Research. 2008;10:e43. [pmid: 19019818].
Bloom JW. The ethical practice of Webcounseling. British Journal of Guidance & Counselling. 1998;26:53-59.
Bobiez KP, Richard DCS. The virtual therapist: Behavior therapy in a digital age. The Behavior Therapist. 2003;26:265-270.
Bock BC, Graham AL, Sciamanna CN, Krishnamoorthy J, Whiteley J, Carmona-Barros R, Abrams D. Smoking cessation treatment on the Internet: Content, quality, and usability. Nicotine & Tobacco Research. 2004;6:207-219. [pmid: 15203794].
Bock BC, Graham AL, Whiteley JA, Stoddard JL. A review of Web-assisted tobacco interventions (WATIs). Journal of Medical Internet Research. 2008;10:e39. [pmid: 19000979].
Boeschoten RE, Nieuwenhuis MM, van Oppen OP, Uitdehaag BM, Polman CH, Collette EH, Dekker J. Feasibility and outcome of a Web-based self-help intervention for depressive symptoms in patients with multiple sclerosis: A pilot study. Journal of the Neurological Sciences. 2012;315:104-109. [pmid: 22133479].
Booker S, Morris M, Johnson A. Empowered to change: Evidence from a qualitative exploration of a user-informed psycho-educational programme for people with type 1 diabetes. Chronic Illness. 2008;4:41-53. [pmid: 18322029].
Booth AO, Nowson CA, Matters H. Evaluation of an interactive, Internet-based weight loss program: A pilot study. Health Education Research. 2008;23:371-381. [pmid: 18349032].
Bopp JM, Miklowitz DJ, Goodwin GM, Stevens W, Rendell JM, Geddes JR. The longitudinal course of bipolar disorder as revealed through weekly text messaging: A feasibility study. Bipolar Disorders. 2010;12:327-334. [pmid: 20565440].
Borzekowski DLG, Leith J, Medoff DR, Potts W, Dixon LB, Balis T, Himelhoch S. Use of the Internet and other media for health information among clinic outpatients with serious mental illness. Psychiatric Services. 2009;60:1265-1268. [pmid: 19723745].
Boschen MJ, Casey LM. The use of mobile telephones as adjuncts to cognitive behavioral psychotherapy. Professional Psychology: Research and Practice. 2008;39:546-552.
Bost RH, Wen FK, Basso MR, Cates GR. Online tools for evaluating patient change: Statistical foundations, clinical applications, research relevance. Rehabilitation Psychology. 2008;53:313-320.
Botella C, Gallego MJ, Garcia-Palacios A, Baños RM, Quero S, Guillen V. An Internet-based self-help program for the treatment of fear of public speaking: A case study. Journal of Technology in Human Services. 2008;26:182-202.
Botella C, Gallego MJ, Garcia-Palacios A, Guillen V, Baños RM, Quero S, Alcañiz M. An Internet-based self-help treatment for fear of public speaking: A controlled trial. CyberPsychology, Behavior and Social Networking. 2010;13:407-421.
Botella C, Guillen V, Garcia-Palacios A, Gallego MJ, Baños RM, Alcaniz M. Telepsychology and self-help: The treatment of fear of public speaking. Cognitive and Behavioral Practice. 2007;14:46-57.
Botella C, Hofmann SG, Moscovitch DA. A self-applied, Internet-based intervention for fear of public speaking. Journal of Clinical Psychology. 2004;60:821-830. [pmid: 15241810].
Botella C, Quero S, Baños RM, Garcia-Palacios A, Breton-Lopez J, Alcañiz M, Fabregat S. Telepsychology and self-help: The treatment of phobias using the Internet. Cyberpsychology & Behavior. 2008;11:659-664. [pmid: 18991528].
Botella C, Quero S, Baños RM, Perpiñá C, Garcia-Palacios A, Riva G. Virtual reality and psychotherapy. Riva G, Botella C, Legeron P, Optale G, editors. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:37-54. Amsterdam. Ios Press.
Botella C, Villa H, Garcia-Palacios A, Quero S, Baños RM, Alcaniz M. The use of VR in the treatment panic disorders and agoraphobia. Riva G, Botella C, Legeron P, Optale G, editors. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:73-90. Amsterdam. Ios Press.
Bouchard S, Payeur R, Rivard V, Allard M, Paquin B, Renaud P, Lapierre J. Cognitive behavior therapy for panic disorder with agoraphobia in videoconference: Preliminary results. CyberPsychology & Behavior. 2000;3:999-1007.
Bouchard S, St-Jacques J, Renaud P, Wiederhold BK. Side effects of immersions in virtual reality for people suffering from anxiety disorders. Journal of CyberTherapy and Rehabilitation. 2009;2:127-137.
Boudreaux ED, Bedek KL, Gilles D, Baumann BM, Hollenberg S, Lord SA, Grissom G. The Dynamic Assessment and Referral System for Substance Abuse (DARSSA): Development, functionality, and end-user satisfaction. Drug and Alcohol Dependence. 2009;99:37-46. [pmid: 18775606].
Boughn S, Holdom JAJ. Trichotillomania: Women's reports of treatment efficacy. Research in Nursing & Health. 2002;25:135-144. [pmid: 11933007].
Boulos MN, Maramba I, Wheeler S. Wikis, blogs and podcasts: A new generation of Web-based tools for virtual collaborative clinical practice and education. BMC Medical Education. 2006;6:41. [pmid: 16911779].
Bowman D. 2012. Telemedicine bill enables VA providers to practice across state lines. Washington DC. Fierce Health IT.
Boyer EW, Smelson D, Fletcher R, Ziedonis D, Picard RW. Wireless technologies, ubiquitous computing and mobile health: Application to drug abuse treatment and compliance with HIV therapies. Journal of Medical Toxicology. 2010;6:212-216. [pmid: 20623215].
Brattberg G. Internet-based rehabilitation for individuals with chronic pain and burnout: A randomized trial. International Journal of Rehabilitation Research. 2006;29:221-227. [pmid: 16900043].
Brattberg G. Internet-based rehabilitation for individuals with chronic pain and burnout II: A long-term follow-up. International Journal of Rehabilitation Research. 2007;30:231-234. [pmid: 17762769].
Brendryen H, Drozd F, Kraft P. A digital smoking cessation program delivered through Internet and cell phone without nicotine replacement (happy ending): Randomized controlled trial. Journal of Medical Internet Research. 2008;10:e51. [pmid: 19087949].
Brendryen H, Kraft P. Happy ending: A randomized controlled trial of a digital multi–media smoking cessation intervention. Addiction. 2008;103:478-484. [pmid: 18269367].
Brenes GA, Ingram CW, Danhauer SC. Telephone-delivered psychotherapy for late-life anxiety. Psychological Services. 2012;9:219-220. [pmid: 22662740].
Brennan JM Jr. 2013. Using virtual reality to improve resilience. Gahanna, OH. The National Psychologist.
Brigham J, Lessov-Schlaggar NC, Javitz SH, Krasnow ER, McElroy M, Swan EG. Test-retest reliability of Web-based retrospective self-report of tobacco exposure and risk. Journal of Medical Internet Research. 2009;11:e35. [pmid: 19674962].
Broda A, LaPlante DA, Nelson SE, LaBrie RA, Bosworth LB, Shaffer HJ. Virtual harm reduction efforts for Internet gambling: Effects of deposit limits on actual Internet sports gambling behavior. Harm Reduction Journal. 2008;5:27. [pmid: 18684323].
Brodey BB, Rosen CS, Brodey IS, Sheetz BM, Steinfeld RR, Gastfriend DR. Validation of the Addiction Severity Index (ASI) for Internet and automated telephone self-report administration. Journal of Substance Abuse Treatment. 2004;26:253-259. [pmid: 15182889].
Brodey BB, Rosen CS, Brodey IS, Sheetz B, Unutzer J. Reliability and acceptability of automated telephone surveys among Spanish- and English-speaking mental health services recipients. Mental Health Services Research. 2005;7:181-184. [pmid: 16194003].
Brohi K. Use of the Internet to improve trauma care. Trauma. 2003;5:117-122.
Bronisch T. Review of new media and suicidality: Perils and possibilities of intervention. Archives of Suicide Research. 2004;8:398-399.
Brookes A. Is cyberspace the next frontier for adventure-based counseling?. Journal of Experiential Education. 1993;16:18-24.
Brooks AC, Ryder D, Carise D, Kirby KC. Feasibility and effectiveness of computer-based therapy in community treatment. Journal of Substance Abuse Treatment. 2010;39:227-235. [pmid: 20667682].
Brooks E, Manson SM, Bair B, Dailey N, Shore JH. The diffusion of telehealth in rural American Indian communities: A retrospective survey of key stakeholders. Telemedicine Journal and e-Health. 2012;18:60-66. [pmid: 22082106].
Broom A. Virtually he@lthy: The impact of Internet use on disease experience and the doctor-patient relationship. Qualitative Health Research. 2005;15:325-345. [pmid: 15761103].
Brotsky SR, Giles D. Inside the “pro-ana” community: A covert online participant observation. Eating Disorders: The Journal of Treatment & Prevention. 2007;15:93-109.
Brouwer W, Oenema A, Crutzen R, de Nooijer J, De Vries N, Brug J. An exploration of factors related to dissemination of and exposure to Internet-delivered behavior change interventions aimed at adults: A Delphi Study approach. Journal of Medical Internet Research. 2008;10:e10. [pmid: 18417443].
Brouwer W, Kroeze W, Crutzen R, de Nooijer J, de Vries NK, Brug J, Oenema A. Which intervention characteristics are related to more exposure to Internet-delivered healthy lifestyle promotion interventions? A systematic review. Journal of Medical Internet Research. 2011;13:e2. [pmid: 21212045].
Brouwer W, Oenema A, Crutzen R, de Nooijer J, de Vries NK, Brug J. What makes people decide to visit and use an Internet-delivered behavior-change intervention? A qualitative study among adults. Health Education. 2009;109:460-473.
Brown D. The odyssey of a technologically challenged counselor educator into cyberspace. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:51-64. Alexandria, VA. American Counseling Association.
Brown JB, Winzelberg AJ, Abascal LB, Taylor CB. An evaluation of an Internet-delivered eating disorder prevention program for adolescents and their parents. Journal of Adolescent Health. 2004;35:290-296. [pmid: 15450542].
Brunette MF, Ferron JC, McHugo GJ, Davis KE, Devitt TS, Wilkness SM, Drake RE. An electronic decision support system to motivate people with severe mental illnesses to quit smoking. Psychiatric Services. 2011;62:360-366. [pmid: 21459986].
Brunsting S, Putte BVD. Web-based computer-tailored feedback on alcohol use: motivating excessive drinkers to consider their behavior. The Internet and health care: Theory, research, and practice. 2006:313-333. Mahwah, NJ. Lawrence Erlbaum Associates Publishers.
Budman SH. Behavioral health care dot-com and beyond: Computer-mediated communications in mental health and substance abuse treatment. American Psychologist. 2000;55:1290-1300. [pmid: 11280939].
Budman SH, Portnoy D, Villapiano AJ. How to get technological innovation used in behavioral health care: Build it and they still might not come. Psychotherapy: Theory, Research, Practice, Training. 2003;40:45-54.
Budney AJ, Fearer S, Walker DD, Stanger C, Thostenson J, Grabinski M, Bickel WK. An initial trial of a computerized behavioral intervention for cannabis use disorder. Drug and Alcohol Dependence. 2010;115(1–2):74-79. [pmid: 21131143].
Buglione SA, DeVito AJ, Mulloy JM. Traditional group therapy and computer-administered treatment for test anxiety. Anxiety Research. 1990;3:33-39.
Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain. 2004;111:368-377. [pmid: 15363881].
Bull SS, Gaglio B, McKay HG, Glasgow RE. Harnessing the potential of the Internet to promote chronic illness self-management: Diabetes as an example of how well we are doing. Chronic Illness. 2005;1:143-155. [pmid: 17136920].
Bunz U. The computer-email-web (CEW) fluency scale – Development and validation. International Journal of Human–Computer Interaction. 2004;17:479-506.
Burgess N, Christensen H, Leach LS, Farrer L, Griffiths KM. Mental health profile of callers to a telephone counselling service. Journal of Telemedicine and Telecare. 2008;14:42-47. [pmid: 18318929].
Burleson JA, Kaminer Y. Aftercare for adolescent alcohol use disorder: Feasibility and acceptability of a phone intervention. The American Journal on Addictions. 2007;16:202-205. [pmid: 17612824].
Burleson JA, Kaminer Y, Burke RH. Twelve-month follow-up of aftercare for adolescents with alcohol use disorders. Journal of Substance Abuse Treatment. 2012;42:78-86. [pmid: 21868186].
Bush NE, Bosmajian CP, Fairall JM, McCann RA, Ciulla RP. Afterdeployment.org: A Web-based multimedia wellness resource for the postdeployment military community. Professional Psychology: Research and Practice. 2011;42:455-462.
Bush NE, Fullerton N, Crumpton R, Metzger-Abamukong M, Fantelli E. Soldiers' personal technologies on deployment and at home. Telemedicine Journal and e-Health. 2012;18:253-263. [pmid: 22400971].
Butcher JN, Perry JN, Atlis MM. Validity and utility of computer-based test interpretation. Psychological Assessment. 2000;12:6-18. [pmid: 10752359].
Butcher JN, Perry J, Hahn J. Computers in clinical assessment: historical developments, present status, and future challenges. Journal of Clinical Psychology. 2004;60:331-345. [pmid: 14981795].
Butler LH, Correia CJ. Brief alcohol intervention with college student drinkers: Face-to-face versus computerized feedback. Psychology of Addictive Behaviors. 2009;23:163-167. [pmid: 19290702].
Butler SF, Budman SH, Goldman RJ, Newman FL, Beckley KE, Trottier D, Cacciola JS. Initial validation of a computer-administered Addiction Severity Index: The ASI-MV. Psychology of Addictive Behaviors. 2001;15:4-12. [pmid: 11255937].
Butler SF, Redondo JP, Fernandez KC, Villapiano A. Validation of the Spanish Addiction Severity Index Multimedia Version (S-ASI-MV). Drug and Alcohol Dependence. 2009;99:18-27. [pmid: 18718727].
Butler SF, Villapiano A, Malinow A. The effect of computer-mediated administration on self-disclosure of problems on the addiction severity index. Journal of Addiction Medicine. 2009;3:194-203. [pmid: 20161486].
Butler TN, Yellowlees P. Cost analysis of store-and-forward telepsychiatry as a consultation model for primary care. Telemedicine Journal and e-Health. 2012;18:74-77. [pmid: 22085113].
Button KS, Wiles NJ, Lewis G, Peters TJ, Kessler D. Factors associated with differential response to online cognitive behavioural therapy. Social Psychiatry and Psychiatric Epidemiology. 2012;47:827-833. [pmid: 21541696].
Buzza C, Ono SS, Turvey C, Wittrock S, Noble M, Reddy G, Reisinger HS. Distance is relative: Unpacking a principal barrier in rural healthcare. Journal of General Internal Medicine. Suppl 2. 2011;26:648-654. [pmid: 21989617].
Bylund CL, Gueguen JA, D'Agostino TA, Imes RS, Sonet E. Cancer patients' decisions about discussing Internet information with their doctors. Psycho-Oncology. 2009;18:1139-1146. [pmid: 19137507].
Bylund CL, Gueguen JA, D'Agostino TA, Li Y, Sonet E. Doctor-patient communication about cancer-related Internet information. Journal of Psychosocial Oncology. 2009;28:127-142. [pmid: 20391071].
Byrne AM, Hartley MT. Digital technology in the 21st century: Considerations for clinical supervision in rehabilitation education. Rehabilitation Education. 2010;24:57-68.
Cafolla R. An introduction to the Internet for independent group therapists. Journal of Psychotherapy in Independent Practice. 2000;1:77-86.
Calear AL, Christensen H. Review of Internet-based prevention and treatment programs for anxiety and depression in children and adolescents. Medical Journal of Australia. 2010;192:S12-S14. [pmid: 20528700].
Calear AL, Christensen H, Mackinnon A, Griffiths KM, O'Kearney R. The YouthMood Project: A cluster randomized controlled trial of an online cognitive behavioral program with adolescents. Journal of Consulting and Clinical Psychology. 2009;77:1021-1032. [pmid: 19968379].
Callan JA, Howland RH, Puskar K. Using computers and the Internet for psychiatric nursing intervention. Journal of Psychosocial Nursing and Mental Health Services. 2009;47:13-14.
Callan JA, Wright JH. Mood disorders. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:3-26. New York. Routledge/Taylor & Francis Group.
Campbell AJ, Cumming SR, Hughes I. Internet use by the socially fearful: Addiction or therapy?. CyberPsychology & Behavior. 2006;9:69-81. [pmid: 16497120].
Campbell AN, Miele GM, Nunes EV, McCrimmon S, Ghitza UE. Web-based, psychosocial treatment for substance use disorders in community treatment settings. Psychological Services. 2012;9:212-214. [pmid: 22662738].
Cantelmi T, Talli M. Trapped in the Web: The psychopathology of cyberspace. Journal of CyberTherapy and Rehabilitation. 2009;2:337-350.
Cardenas G, Serrano B, Flores LA, De La Rosa A. Etherapy: A training program for development of clinical skills in distance psychotherapy. Journal of Technology in Human Services. 2008;26:470-488.
Carey JC, Wade SL, Wolfe CR. Lessons learned: The effect of prior technology use on Web-based interventions. CyberPsychology & Behavior. 2008;11:188-195. [pmid: 18422412].
Carey KB, Scott-Sheldon LA, Elliott JC, Bolles JR, Carey MP. Computer-delivered interventions to reduce college student drinking: A meta-analysis. Addiction. 2009;104:1807-1819. [pmid: 19744139].
Carise D, Gurel O, McLellan AT, Dugosh K, Kendig C. Getting patients the services they need using a computer-assisted system for patient assessment and referral—CASPAR. Drug and Alcohol Dependence. 2005;80:177-189. [pmid: 15913922].
Carlbring P, Andersson G. Internet and psychological treatment. How well can they be combined?. Computers in Human Behavior. 2006;22:545-553.
Carlbring P, Bohman S, Brunt S, Buhrman M, Westling BE, Ekselius L, Andersson G. Remote treatment of panic disorder: A randomized trial of Internet-based cognitive behavior therapy supplemented with telephone calls. American Journal of Psychiatry. 2006;163:2119-2125. [pmid: 17151163].
Carlbring P, Brunt S, Bohman S, Austin D, Richards J, Ost LG, Andersson G. Internet vs. paper and pencil administration of questionnaires commonly used in panic/agoraphobia research. Computers in Human Behavior. 2007;23:1421-1434.
Carlbring P, Degerman N, Jonsson J, Andersson G. Internet-based treatment of pathological gambling with a three-year follow-up. Cognitive Behaviour Therapy. 2012;41(4):321-334. [pmid: 22620990].
Carlbring P, Ekselius L, Andersson G. Treatment of panic disorder via the Internet: A randomized trial of CBT vs. applied relaxation. Journal of Behavior Therapy and Experimental Psychiatry. 2003;34:129-140. [pmid: 12899896].
Carlbring P, Furmark T, Steczko J, Ekselius L, Andersson G. An open study of Internet-based bibliotherapy with minimal therapist contact via email for social phobia. Clinical Psychologist. 2006;10:30-38.
Carlbring P, Gunnarsdóttir M, Hedensjö L, Andersson G, Ekselius L, Furmark T. Treatment of social phobia: Randomised trial of Internet-delivered cognitive–behavioural therapy with telephone support. British Journal of Psychiatry. 2007;190:123-128. [pmid: 17267928].
Carlbring P, Maurin L, Torngren C, Linna E, Eriksson T, Sparthan E, Andersson G. Individually-tailored, Internet-based treatment for anxiety disorders: A randomized controlled trial. Behaviour Research and Therapy. 2011;49:18-24. [pmid: 21047620].
Carlbring P, Nilsson-Ihrfelt E, Waara J, Kollenstam C, Buhrman M, Kaldo V, Andersson G. Treatment of panic disorder: Live therapy vs. self-help via the. Internet Behaviour Research and Therapy. 2005;43:1321-1333. [pmid: 16086983].
Carlbring P, Nordgren LB, Furmark T, Andersson G. Long-term outcome of Internet-delivered cognitive-behavioural therapy for social phobia: A 30-month follow-up. Behaviour Research and Therapy. 2009;47:848-850. [pmid: 19631312].
Carlbring P, Smit F. Randomized trial of Internet-delivered self-help with telephone support for pathological gamblers. Journal of Consulting and Clinical Psychology. 2008;76:1090-1094. [pmid: 19045977].
Carlbring P, Westling BE, Ljungstrand P, Ekselius L, Andersson G. Treatment of panic disorder via the Internet: A randomized trial of a self-help program. Behavior Therapy. 2001;32:751-764.
Carlson-Sabelli L. Using forums to enrich counselor training and supervision. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:415-420. Springfield, IL. Charles C. Thomas Publisher.
Carneal G. 2012. 2010 Health Information Technology Survey: How technology is changing the practice of care management. Annapolis, MD. Schooner Health.
Carr AC, Ghosh A, Marks IM. Computer-supervised exposure treatment for phobias. Canadian Journal of Psychiatry/La Revue Canadienne de Psychiatrie. 1988;33:112-117.
Carrard I, Crepin C, Rouget P, Lam T, Golay A, Van der Linden M. Randomised controlled trial of a guided self-help treatment on the Internet for binge eating disorder. Behaviour Research and Therapy. 2011;49:482-491. [pmid: 21641580].
Carrard I, Fernández-Aranda F, Lam T, Nevonen L, Liwowsky I, Volkart AC, Norring C. Evaluation of a guided Internet self-treatment programme for bulimia nervosa in several European countries. European Eating Disorders Review. 2011;19:138-149. [pmid: 20859989].
Carrard I, Rouget P, Fernández-Aranda F, Volkart AC, Damoiseau M, Lam T. Evaluation and deployment of evidence based patient self-management support program for bulimia nervosa. International Journal of Medical Informatics. 2006;75:101-109. [pmid: 16115793].
Carroll KM, Ball SA, Martino S, Nich C, Babuscio TA, Rounsaville BJ. Enduring effects of a computer-assisted training program for cognitive behavioral therapy: A 6-month follow-up of CBT4CBT. Drug and Alcohol Dependence. 2009;100:178-181. [pmid: 19041197].
Carroll KM, Ball SA, Martino S, Nich C, Babuscio TA, Nuro KF, Rounsaville BJ. Computer-assisted delivery of cognitive-behavioral therapy for addiction: A randomized trial of CBT4CBT. American Journal of Psychiatry. 2008;165:881-888. [pmid: 18450927].
Carroll KM, Kiluk BD, Nich C, Babuscio TA, Brewer JA, Potenza MN, Lejuez CW. Cognitive function and treatment response in a randomized clinical trial of computer-based training in cognitive-behavioral therapy. Substance Use & Misuse. 2011;46:23-34. [pmid: 21190403].
Carroll KM, Kiluk BD, Nich C, Gordon MA, Portnoy GA, Marino DR, Ball SA. Computer-assisted delivery of cognitive-behavioral therapy: Efficacy and durability of CBT4CBT among cocaine-dependent individuals maintained on methadone. American Journal of Psychiatry. 2014;171(4):436-444. [pmid: 24577287].
Carroll KM, Nich C, Ball SA. Practice makes progress? Homework assignments and outcome in treatment of cocaine dependence. Journal of Consulting and Clinical Psychology. 2005;73:749-755. [pmid: 16173864].
Carroll KM, Rounsaville BJ. Computer-assisted therapy in psychiatry: Be brave–it's a new world. Current Psychiatry Reports. 2010;12:426-432. [pmid: 20683681].
Carter RE, Haynes LF, Back SE, Herrin AE, Brady KT, Leimberger JD, Liepman MR. Improving the transition from residential to outpatient addiction treatment: Gender differences in response to supportive telephone calls. American Journal of Drug and Alcohol Abuse. 2008;34:47-59. [pmid: 18161643].
Cartreine JA, Ahern DK, Locke SE. A roadmap to computer-based psychotherapy in the United States. Harvard Review of Psychiatry. 2010;18:80-95. [pmid: 20235773].
Casey JA. Managing technology wisely: A new counselor competency. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:17-28. Alexandria, VA. American Counseling Association.
Cash CD. Telepsychiatry and risk management. Innovations in Clinical Neuroscience. 2011;8:26-30. [pmid: 22010063].
Caspar F. Technological developments and applications in clinical psychology and psychotherapy: Introduction. Journal of Clinical Psychology. 2004;60:221-238. [pmid: 14981788].
Caspar F. Technological developments and applications in clinical psychology and psychotherapy: Summary and outlook. Journal of Clinical Psychology. 2004;60:347-349. [pmid: 14981796].
Caspar F, Berger T. The future is bright: How can we optimize online counseling, and how can we know whether we have done so?. Counseling Psychologist. 2005;33:900-909.
Castelnuovo G, Buselli C, De Ferrari R, Gaggioli A, Mantovani F, Molinari E, Riva G. New tools in cybertherapy: The VEPSY Web site. Riva G, Botella C, Legeron P, Optale G, editors. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:15-36. Amsterdam. Ios Press.
Castelnuovo G, Gaggioli A, Mantovani F, Riva G. From psychotherapy to e-therapy: The integration of traditional techniques and new communication tools in clinical settings. CyberPsychology & Behavior. 2003;6:375-382. [pmid: 14511449].
Castelnuovo G, Gaggioli A, Mantovani F, Riva G. New and old tools in psychotherapy: The use of technology for the integration of the traditional clinical treatments. Psychotherapy: Theory, Research, Practice, Training. 2003;40:33-44.
Castelnuovo G, Gaggioli A, Riva G. Cyberpsychology meets clinical psychology: The emergence of e-therapy in mental health care. Towards cyberpsychology: Mind, cognition and society in the Internet age. 2001:229-252. Amsterdam, Netherlands. Ios Press.
Cavanagh K, Shapiro DA, Van Den Berg S, Swain S, Barkham M, Proudfoot J. The effectiveness of computerized cognitive behavioural therapy in routine care. British Journal of Clinical Psychology. 2006;45:499-514. [pmid: 17076960].
Cavanagh K, Shapiro DA, Van Den Berg S, Swain S, Barkham M, Proudfoot J. The acceptability of computer-aided cognitive behavioural therapy: A pragmatic study. Cognitive Behaviour Therapy. 2009;38:235-246. [pmid: 19306147].
Celio AA, Winzelberg AJ, Wilfley DE, Eppstein-Herald D, Springer EA, Dev P, Taylor CB. Reducing risk factors for eating disorders: Comparison of an Internet- and a classroom-delivered psychoeducational program. Journal of Consulting and Clinical Psychology. 2000;68:650-657. [pmid: 10965640].
Center for Substance Abuse Treatment. 1993. Improving treatment for drug-exposed infants. Treatment Improvement Protocol (TIP) Series 5. HHS Publication No. (SMA) 95-3057. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Pregnant, substance-using women. Treatment Improvement Protocol (TIP) Series 2. HHS Publication No. (SMA) 93-1998. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Screening for infectious diseases among substance abusers. Treatment Improvement Protocol (TIP) Series 6. HHS Publication No. (SMA) 95-3060. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1994. Simple screening instruments for outreach for alcohol and other drug abuse and infectious diseases. Treatment Improvement Protocol (TIP) Series 11. HHS Publication No. (SMA) 94-2094. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Alcohol and other drug screening of hospitalized trauma patients. Treatment Improvement Protocol (TIP) Series 16. HHS Publication No. (SMA) 95-3041. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Combining alcohol and other drug treatment with diversion for juveniles in the justice system. Treatment Improvement Protocol (TIP) Series 21. HHS Publication No. (SMA) 95-3051. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Developing state outcomes monitoring systems for alcohol and other drug abuse treatment. Treatment Improvement Protocol (TIP) Series 14. HHS Publication No. (SMA) 95-3031. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The role and current status of patient placement criteria in the treatment of substance use disorders. Treatment Improvement Protocol (TIP) Series 13. HHS Publication No. (SMA) 95-3021. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The tuberculosis epidemic: Legal and ethical issues for alcohol and other drug abuse treatment providers. Treatment Improvement Protocol (TIP) Series 18. HHS Publication No. (SMA) 95-3047. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1996. Treatment drug courts: Integrating substance abuse treatment with legal case processing. Treatment Improvement Protocol (TIP) Series 23. HHS Publication No. (SMA) 96-3113. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. A guide to substance abuse services for primary care clinicians. Treatment Improvement Protocol (TIP) Series 24. HHS Publication No. (SMA) 97-3139. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. Substance abuse treatment and domestic violence. Treatment Improvement Protocol (TIP) Series 25. HHS Publication No. (SMA) 97-3163. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Comprehensive case management for substance abuse treatment. Treatment Improvement Protocol (TIP) Series 27. HHS Publication No. (SMA) 98-3222. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Continuity of offender treatment for substance use disorders from institution to community. Treatment Improvement Protocol (TIP) Series 30. HHS Publication No. (SMA) 98-3245. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Naltrexone and alcoholism treatment. Treatment Improvement Protocol (TIP) Series 28. HHS Publication No. (SMA) 98-3206. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance abuse among older adults. Treatment Improvement Protocol (TIP) Series 26. HHS Publication No. (SMA) 98-3179. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance use disorder treatment for people with physical and cognitive disabilities. Treatment Improvement Protocol (TIP) Series 29. HHS Publication No. (SMA) 98-3249. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Brief interventions and brief therapies for substance abuse. Treatment Improvement Protocol (TIP) Series 34. HHS Publication No. (SMA) 99-3353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Enhancing motivation for change in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 35. HHS Publication No. (SMA) 99-3354. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Screening and assessing adolescents for substance use disorders. Treatment Improvement Protocol (TIP) Series 31. HHS Publication No. (SMA) 99-3282. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment of adolescents with substance use disorders. Treatment Improvement Protocol (TIP) Series 32. HHS Publication No. (SMA) 99-3283. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment for stimulant use disorders. Treatment Improvement Protocol (TIP) Series 33. HHS Publication No. (SMA) 99-3296. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Integrating substance abuse treatment and vocational services. Treatment Improvement Protocol (TIP) Series 38. HHS Publication No. (SMA) 00-3470. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with child abuse and neglect issues. Treatment Improvement Protocol (TIP) Series 36. HHS Publication No. (SMA) 00-3357. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37. HHS Publication No. (SMA) 00-3459. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Clinical guidelines for the use of buprenorphine in the treatment of opioid addiction. Treatment Improvement Protocol (TIP) Series 40. HHS Publication No. (SMA) 04-3939. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Substance abuse treatment and family therapy. Treatment Improvement Protocol (TIP) Series 39. HHS Publication No. (SMA) 04-3957. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Medication-assisted treatment for opioid addiction. Treatment Improvement Protocol (TIP) Series 43. HHS Publication No. SMA 05-4048. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for adults in the criminal justice system. Treatment Improvement Protocol (TIP) Series 44. HHS Publication No. (SMA) 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for persons with co-occurring disorders. Treatment Improvement Protocol (TIP) Series 42. HHS Publication No. SMA 05-3992. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment: Group therapy. Treatment Improvement Protocol (TIP) Series 41. HHS Publication No. SMA 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Detoxification and substance abuse treatment. Treatment Improvement Protocol (TIP) Series 45. HHS Publication No. SMA 06-4131. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Administrative issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 46. HHS Publication No. SMA 06-4151. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Clinical issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 47. HHS Publication No. SMA 06-4182. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2008. Managing depressive symptoms in substance abuse clients during early recovery. Treatment Improvement Protocol (TIP) Series 48. HHS Publication No. SMA 08-4353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Addressing suicidal thoughts and behaviors in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 50. HHS Publication No. SMA 09-4381. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Clinical supervision and the professional development of the substance abuse counselor. Treatment Improvement Protocol (TIP) Series 52. HHS Publication No. SMA 09-4435. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Considerations for the provision of e-therapy. HHS Publication. No. (SMA) 09–4450. Rockville, MD. Center for Substance Abuse Treatment, Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Incorporating alcohol pharmacotherapies into medical practice. Treatment Improvement Protocol (TIP) Series 49. HHS Publication No. SMA 09-4380. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Substance abuse treatment: Addressing the specific needs of women. Treatment Improvement Protocol (TIP) Series 51. HHS Publication No. SMA 09-4426. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Chambers M, Connors SL, McElhinney S. Substance use and young people: The potential of technology. Journal of Psychiatric and Mental Health Nursing. 2005;12:179-186. [pmid: 15788035].
Chandler GM, Burck H, Sampson JP, Wray R. The effectiveness of a generic computer program for systematic desensitization. Computers in Human Behavior. 1988;4:339-346.
Chang T, Chang R. Counseling and the Internet: Asian American and Asian international college students' attitudes toward seeking online professional psychological help. Journal of College Counseling. 2004;7:140-149.
Chang T. Online counseling: Prioritizing psychoeducation, self-help, and mutual help for counseling psychology research and practice. Counseling Psychologist. 2005;33:881-890.
Chen HH, Yeh ML. Developing and evaluating a smoking cessation program combined with an Internet-assisted instruction program for adolescents with smoking. Patient Education and Counseling. 2006;61:411-418. [pmid: 16125357].
Chen HH, Yeh ML, Chao YH. Comparing effects of auricular acupressure with and without an Internet-assisted program on smoking cessation and self-efficacy of adolescents. The Journal of Alternative and Complementary Medicine. 2006;12:147-152. [pmid: 16566674].
Chen YF, Madan J, Welton N, Yahaya I, Aveyard P, Bauld L, Munafò MR. Effectiveness and cost-effectiveness of computer and other electronic aids for smoking cessation: A systematic review and network meta-analysis. Health Technology Assessment. 2012;16:iii-v.
Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: A randomized controlled trial. Journal of Zhejiang University Science B. 2008;9:34-38. [pmid: 18196610].
Cheon J, Grant M. Active listening: Web-based assessment tool for communication and active listening skill development. TechTrends. 2009;53:24-34.
Chester A, Glass CA. Online counselling: A descriptive analysis of therapy services on the Internet. British Journal of Guidance & Counselling. 2006;34:145-160.
Chiauzzi E, Brevard J, Thurn C, Decembrele S, Lord S. MyStudentBody–stress: An online stress management intervention for college students. Journal of Health Communication. 2008;13:555-572. [pmid: 18726812].
Chiauzzi E, Green TC, Lord S, Thum C, Goldstein M. My Student Body: A high-risk drinking prevention Web site for college students. Journal of American College Health. 2005;53:263-274. [pmid: 15900990].
Chiauzzi E, Pujol LA, Wood M, Bond K, Black R, Yiu E, Zacharoff K. painACTION–Back Pain: A self-management Website for people with chronic back pain. Pain Medicine. 2010;11:1044-1058. [pmid: 20545873].
Childress CA. Interactive e-mail journals: A model for providing psychotherapeutic interventions using the Internet. CyberPsychology & Behavior. 1999;2:213-221. [pmid: 19178238].
Childress CA. Ethical issues in providing online psychotherapeutic interventions. Journal of Medical Internet Research. 2000;2:E5. [pmid: 11720924].
Chinman M, Hassell J, Magnabosco J, Nowlin-Finch N, Marusak S, Young AS. The feasibility of computerized patient self-assessment at mental health clinics. Administration and Policy in Mental Health. 2007;34:401-409. [pmid: 17453332].
Chinman M, Tremain B, Imm P, Wandersman A. Strengthening prevention performance using technology: A formative evaluation of interactive getting to outcomes. American Journal of Orthopsychiatry. 2009;79:469-481. [pmid: 20099938].
Chipps J, Brysiewicz P, Mars M. Effectiveness and feasibility of telepsychiatry in resource constrained environments? A systematic review of the evidence. African Journal of Psychiatry (Johannesburg). 2012;15:235-243.
Chipps J, Ramlall S, Mars M. Practice guidelines for videoconference-based telepsychiatry in South Africa. African Journal of Psychiatry (Johannesburg). 2012;15:271-282.
Chirban JT. Integrative strategies for treating Internet sexuality: A case study of paraphilias. Clinical Case Studies. 2006;5:126-141.
Chiu T, Marziali E, Colantonio A, Carswell A, Gruneir M, Tang M, Eysenbach G. Internet-based caregiver support for Chinese Canadians taking care of a family member with Alzheimer disease and related dementia. Canadian Journal on Aging/La Revue Canadienne du Vieillissement. 2009;28:323-336.
Cho JH, Lee HC, Lim DJ, Kwon HS, Yoon KH. Mobile communication using a mobile phone with a glucometer for glucose control in Type 2 patients with diabetes: as effective as an Internet-based glucose monitoring system. Journal of Telemedicine and Telecare. 2009;15:77-82. [pmid: 19246607].
Choi I, Zou J, Titov N, Dear BF, Li S, Johnston L, Hunt C. Culturally attuned Internet treatment for depression amongst Chinese Australians: A randomised controlled trial. Journal of Affective Disorders. 2012;136:459-468. [pmid: 22177742].
Chong J, Moreno F. Feasibility and acceptability of clinic-based telepsychiatry for low-income Hispanic primary care patients. Telemedicine Journal and e-Health. 2012;18:297-304. [pmid: 22424078].
Chou SW, Hunt MY, Beckjord BE, Moser PR, Hesse WB. Social media use in the United States: Implications for health communication. Journal of Medical Internet Research. 2009;11:e48. [pmid: 19945947].
Choudhury T, Consolvo S, Harrison B, LaMarca A, LeGrand L, Rahimi A, Haehnel D. The mobile sensing platform: An embedded activity recognition system. IEEE Pervasive Computing. 2008;7:32-41.
Christensen H, Griffiths K. The Internet and mental health literacy. Australian and New Zealand Journal of Psychiatry. 2000;34:975-979. [pmid: 11127628].
Christensen H, Griffiths K, Farrer L. Adherence in Internet interventions for anxiety and depression: Systematic review. Journal of Medical Internet Research. 2009;11:e13. [pmid: 19403466].
Christensen H, Griffiths K, Groves C, Korten A. Free range users and one hit wonders: Community users of an Internet-based cognitive behaviour therapy program. Australian and New Zealand Journal of Psychiatry. 2006;40:59-62. [pmid: 16403040].
Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the Internet: Randomised controlled trial. BMJ. 2004;328:265. [pmid: 14742346].
Christensen H, Griffiths KM, Korten A. Web-based cognitive behavior therapy: Analysis of site usage and changes in depression and anxiety scores. Journal of Medical Internet Research. 2002;4:e3. [pmid: 11956035].
Christensen H, Griffiths KM, Korten AE, Brittliffe K, Groves C. A comparison of changes in anxiety and depression symptoms of spontaneous users and trial participants of a cognitive behavior therapy Website. Journal of Medical Internet Research. 2004;6:e46. [pmid: 15631970].
Christensen H, Griffiths KM, Mackinnon AJ, Brittliffe K. Online randomized controlled trial of brief and full cognitive behaviour therapy for depression. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2006;36:1737-1746.
Christensen H, Murray K, Calear AL, Bennett K, Bennett A, Griffiths KM. Beacon: A Web portal to high-quality mental health Websites for use by health professionals and the public. Medical Journal of Australia. 2010;192:S40-S44. [pmid: 20528708].
Christmas DMB. ‘Brain shivers’: From chat room to clinic. Psychiatric Bulletin. 2005;29:219-221.
Chung-Do J, Helm S, Fukuda M, Alicata D, Nishimura S, Else I. Rural mental health: Implications for telepsychiatry in clinical service, workforce development, and organizational capacity. Telemedicine and e-Health. 2012;18:244-246. [pmid: 22356526].
Clark G. Traditional uses of technology in counseling trainee supervision. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:256-268. Springfield, IL. Charles C. Thomas Publisher.
Clark G, Horan JJ, Tompkins-Bjorkman A, Kovalski T, Hackett G. Interactive career counseling on the Internet. Journal of Career Assessment. 2000;8:85-93.
Clarke G, Eubanks D, Reid E, Kelleher C, O'Connor E, DeBar LL, Gullion C. Overcoming depression on the Internet (ODIN) (2): A randomized trial of a self-help depression skills program with reminders. Journal of Medical Internet Research. 2005;7:e16. [pmid: 15998607].
Clarke G, Reid E, Eubanks D, O'Connor E, DeBar LL, Kelleher C, Nunley S. Overcoming depression on the Internet (ODIN): A randomized controlled trial of an Internet depression skills intervention program. Journal of Medical Internet Research. 2002;4:E14. [pmid: 12554545].
Clarke J, van Amerom G. A comparison of blogs by depressed men and women. Issues in Mental Health Nursing. 2008;29:243-264. [pmid: 18340611].
Clayman ML, Boberg EW, Makoul G. The use of patient and provider perspectives to develop a patient-oriented Website for women diagnosed with breast cancer. Patient Education and Counseling. 2008;72:429-435. [pmid: 18653304].
Cleary M, Freeman A. Email etiquette: Guidelines for mental health nurses. International Journal of Mental Health Nursing. 2005;14:62-65. [pmid: 15733287].
Cleary M, Walter G, Matheson S. What is the role of e-technology in mental health services and psychiatric research?. Journal of Psychosocial Nursing and Mental Health Services. 2008;46:42-48. [pmid: 18478808].
Clinton BK, Silverman BC, Brendel DH. Patient-targeted googling: The ethics of searching online for patient information. Harvard Review of Psychiatry. 2010;18:103-112. [pmid: 20235775].
Clinton BK, Silverman BC, Brendel DH. Patient-targeted googling: The ethics of searching online for patient information. Harvard Review of Psychiatry. 2010;18:206.
Cloud RN, Peacock PL. Internet screening and interventions for problem drinking: Results from the www.carebetter.com pilot study. Alcoholism Treatment Quarterly. 2001;19:23-44.
Cobb NK. Online consumer search strategies for smoking-cessation information. American Journal of Preventive Medicine. 2010;38:S429-S432. [pmid: 20176318].
Cobb NK, Graham AL. Characterizing Internet searchers of smoking cessation information. Journal of Medical Internet Research. 2006;8:e17. [pmid: 17032633].
Cobb NK, Graham AL, Abrams DB. Social network structure of a large online community for smoking cessation. American Journal of Public Health. 2010;100:1282-1289. [pmid: 20466971].
Cobb NK, Graham AL, Bock BC, Papandonatos G, Abrams DB. Initial evaluation of a real-world Internet smoking cessation system. Nicotine and Tobacco Research. 2005;7:207-216. [pmid: 16036277].
Cohen J, Mannarino AP. Disseminating and implementing trauma–focused CBT in community settings. Trauma, Violence, & Abuse. 2008;9:214-226.
Coiera E. Four rules for the reinvention of health care. BMJ. 2004;328:1197-1199. [pmid: 15142933].
Col NF. Using Internet technologies to improve and simplify counseling about menopause: The WISDOM Website. Maturitas. 2007;57:95-99. [pmid: 17367963].
Cole-Lewis H, Kershaw T. Text messaging as a tool for behavior change in disease prevention and management. Epidemiologic Reviews. 2010;32:56-69. [pmid: 20354039].
Collie KR, Mitchell D, Murphy L. Skills for on-line counseling: Maximum impact at minimum bandwidth. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:219-236. Alexandria, VA. American Counseling Association.
Collins F. How to fulfill the true promise of “mHealth”. Scientific American. 2012;307:16. [pmid: 22779258].
Collins GB, McAllister MS, Ford DB. Patient-provider e-mail communication as an adjunctive tool in addiction medicine. Journal of Addictive Diseases. 2007;26:45-52. [pmid: 17594997].
Collins LH. Practicing safer listserv use: Ethical use of an invaluable resource. Professional Psychology: Research and Practice. 2007;38:690-698.
Collins S, Jerry P. The Campus Alberta Applied Psychology Counselling Initiative: Web-based delivery of a graduate professional training program. Journal of Technology in Human Services. 2005;23:99-119.
Collis B, Winnips K, Moonen J. Structured support versus learner choice via the world wide Web (WWW): Where is the payoff?. Journal of Interactive Learning Research. 2000;11:131-162.
Condon TP, Miner LL, Balmer CW, Pintello D. Blending addiction research and practice: Strategies for technology transfer. Journal of Substance Abuse Treatment. 2008;35:156-160. [pmid: 18337054].
Consolvo S, Landay JA, McDonald DW. Designing for behavior change in everyday life. Computer. 2009;42:86-89.
Constantino R, Crane PA, Noll BS, Doswell WM, Braxter B. Exploring the feasibility of email-mediated interaction in survivors of abuse. Journal of Psychiatric and Mental Health Nursing. 2007;14:291-301. [pmid: 17430453].
Cook JE, Doyle C. Working alliance in online therapy as compared to face-to-face therapy: Preliminary results. CyberPsychology and Behavior. 2002;5:95-105. [pmid: 12025884].
Cook RF, Back AS, Trudeau J, McPherson T. Integrating substance abuse prevention into health promotion programs in the workplace: A social cognitive intervention targeting the mainstream user. Bennett JB, Lehman WEK, editors. Preventing workplace substance abuse: Beyond drug testing to wellness. 2003:97-133. Washington, DC. American Telemedicine Association.
Cook RF, Billings DW, Hersch RK, Back AS, Hendrickson A. A field test of a Web-based workplace health promotion program to improve dietary practices, reduce stress, and increase physical activity: Randomized controlled trial. Journal of Medical Internet Research. 2007;9:e17. [pmid: 17581811].
Cooper G. Exploring and understanding online assistance for problem gamblers: The Pathways Disclosure Model. International Journal of Mental Health and Addiction. 2004;1:32-38.
Copeland J. Application of technology in the prevention and treatment of substance use disorders and related problems: Opportunities and challenges. Substance Use & Misuse. 2011;46:112-113. [pmid: 21190411].
Copeland J, Martin G. Web-based interventions for substance use disorders: A qualitative review. Journal of Substance Abuse Treatment. 2004;26:109-116. [pmid: 15050088].
Coren CM, Nath SR, Prout M. Computer-assisted sensate focus: Integrating technology with sex therapy practice. Journal of Technology in Human Services. 2009;27:273-286.
Costin LD, Mackinnon JA, Griffiths MK, Batterham JP, Bennett JA, Bennett K, Christensen H. Health e-cards as a means of encouraging help seeking for depression among young adults: Randomized controlled trial. Journal of Medical Internet Research. 2009;11:e42. [pmid: 19850549].
Coursol DH, Lewis J, Seymour JW. The use of videoconferencing to enrich counselor training and supervision. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:280-288. Springfield, IL. Charles C. Thomas Publisher.
Cousineau TM, Green TC, Corsini E, Seibring A, Showstack MT, Applegarth L, Perloe M. Online psychoeducational support for infertile women: A randomized controlled trial. Human Reproduction. 2008;23:554-566. [pmid: 18089552].
Coyle D, Doherty G, Matthews M, Sharry J. Computers in talk-based mental health interventions. Interacting with Computers. 2007;19:545-562.
Craske MG, Rose RD, Lang A, Welch SS, Campbell-Sills L, Sullivan G, Roy-Byrne PP. Computer-assisted delivery of cognitive behavioral therapy for anxiety disorders in primary-care settings. Depression and Anxiety. 2009;26:235-242. [pmid: 19212970].
Crawley A, Fetzner M, editors. Journal of Asynchronous Learning Networks. 2013;17:3.
Croom K, Lewis D, Marchell T, Lesser ML, Reyna VF, Kubicki-Bedford L, Staiano-Coico L. Impact of an online alcohol education course on behavior and harm for incoming first-year college students: Short-term evaluation of a randomized trial. Journal of American College Health. 2009;57:445-454. [pmid: 19114384].
Crutzen R, De Nooijer J, Brouwer W, Oenema A, Brug J, de Vries NK. Internet-delivered interventions aimed at adolescents: A Delphi study on dissemination and exposure. Health Education Research. 2008;23:427-439. [pmid: 18209115].
Crutzen R, De Nooijer J, Brouwer W, Oenema A, Brug J, de Vries NK. Qualitative assessment of adolescents' views about improving exposure to Internet-delivered interventions. Health Education. 2008;108:105-116.
Crutzen R, De Nooijer J, Brouwer W, Oenema A, Brug J, de Vries NK. Effectiveness of online word of mouth on exposure to an Internet-delivered intervention. Psychology and Health. 2009;24:651-661. [pmid: 20205018].
Cruz M, Lopez AM. Technologic advancement and the psychiatric encounter. CyberPsychology and Behavior. 2000;3:929-933.
Csipke E, Horne O. Pro-eating disorder Websites: Users' opinions. European Eating Disorders Review. 2007;15:196-206. [pmid: 17676689].
Cucciare MA. Implementation. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:225-245. New York. Routledge/Taylor & Francis Group.
Cucciare MA, Weingardt KR. 2010. Using technology to support evidence-based behavioral health practices: A clinician's guide. New York. Routledge/Taylor & Francis Group.
Cucciare MA, Weingardt KR, Humphreys K. How Internet technology can improve the quality of care for substance use disorders. Current Drug Abuse Reviews. 2009;2:256-262. [pmid: 20443772].
Cuijpers P, Schuurmans J. Self-help interventions for anxiety disorders: An overview. Current Psychiatry Reports. 2007;9:284-290. [pmid: 17880859].
Cuijpers P, Donker T, van Straten A, Li J, Andersson G. Is guided self-help as effective as face-to-face psychotherapy for depression and anxiety disorders? A systematic review and meta-analysis of comparative outcome studies. Psychological Medicine. 2010:1-15.
Cuijpers P, Marks IM, van Straten A, Cavanagh K, Gega L, Andersson G. Computer-aided psychotherapy for anxiety disorders: A meta-analytic review. Cognitive Behaviour Therapy. 2009;38:66-82. [pmid: 20183688].
Cuijpers P, van Straten A, Andersson G. Internet-administered cognitive behavior therapy for health problems: A systematic review. Journal of Behavioral Medicine. 2008;31:169-177. [pmid: 18165893].
Cullen KW, Thompson D. Feasibility of an 8-week African American Web-based pilot program promoting healthy eating behaviors: Family Eats. American Journal of Health Behavior. 2008;32:40-51. [pmid: 18021032].
Cummings JN, Sproull L, Kiesler SB. Beyond hearing: Where the real-world and online support meet. Group Dynamics: Theory, Research, and Practice. 2002;6:78-88.
Cummings P. Cybervision: Virtual peer group counseling supervision—Hindrance or help?. Counselling & Psychotherapy Research. 2002;2:223-229.
Cummins CO, Prochaska JO, Driskell MM, Evers KE, Wright JA, Prochaska JM, Velicer WF. Development of review criteria to evaluate health behavior change Websites. Journal of Health Psychology. 2003;8:55-62. [pmid: 22113900].
Cummins SE, Bailey L, Campbell S, Koon-Kirby C, Zhu SH. Tobacco cessation quitlines in North America: A descriptive study. Tobacco Control. Suppl 1. 2007;16:i9-15. [pmid: 18048639].
Cunningham JA. Access and interest: Two important issues in considering the feasibility of Web-assisted tobacco interventions. Journal of Medical Internet Research. 2008;10:e37. [pmid: 18984558].
Cunningham JA, Hodgins DC, Toneatto T, Murphy M. A randomized controlled trial of a personalized feedback intervention for problem gamblers. PLOS ONE. 2012;7:e31586. [pmid: 22348112].
Cunningham JA, Humphreys K, Koski-Jannes A. Providing personalized assessment feedback for problem drinking on the Internet: A pilot project. Journal of Studies on Alcohol. 2000;61:794-798. [pmid: 11188484].
Cunningham JA, Humphreys K, Koski-Jannes A, Cordingley J. Internet and paper self-help materials for problem drinking: Is there an additive effect?. Addictive Behaviors. 2005;30:1517-1523. [pmid: 15893433].
Cunningham JA, Humphreys K, Kypri K, Van Mierlo T. Formative evaluation and three-month follow-up of an online personalized assessment feedback intervention for problem drinkers. Journal of Medical Internet Research. 2006;8:e5. [pmid: 16867968].
Cunningham JA, Van Mierlo T. Methodological issues in the evaluation of Internet-based interventions for problem drinking. Drug and Alcohol Review. 2009;28:12-17. [pmid: 19320670].
Cunningham JA, Wild TC, Cordingley J, Van Mierlo T, Humphreys K. A randomized controlled trial of an Internet-based intervention for alcohol abusers. Addiction. 2009;104:2023-2032. [pmid: 19922569].
Cunningham JA, Wild TC, Cordingley J, Van Mierlo T, Humphreys K. Twelve-month follow-up results from a randomized controlled trial of a brief personalized feedback intervention for problem drinkers. Alcohol and Alcoholism. 2010;45:258-262. [pmid: 20150170].
Currie SL, McGrath PJ, Day V. Development and usability of an online CBT program for symptoms of moderate depression, anxiety, and stress in post-secondary students. Computers in Human Behavior. 2010;26:1419-1426.
Curtis B. Understanding tailored Internet smoking cessation messages: A reasoned action approach. Annals of the American Academy of Political and Social Science. 2012;640:136-149.
Cussler EC, Teixeira PJ, Going SB, Houtkooper LB, Metcalfe LL, Blew RM, Lohman TG. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity. 2008;16:1052-1060. [pmid: 18309301].
Dale J, Caramlau IO, Lindenmeyer A, Williams SM. 2008. Peer support telephone calls for improving health. Cochrane Database of Systematic Reviews. CD006903.
Daley ML, Becker DF, Flaherty LT, Harper G, King RA, Lester P, Schwab-Stone M. Case study: The Internet as a developmental tool in an adolescent boy with psychosis. Journal of the American Academy of Child and Adolescent Psychiatry. 2005;44:187-190. [pmid: 15689732].
Dallery J, Glenn IM. Effects of an Internet-based voucher reinforcement program for smoking abstinence: A feasibility study. Journal of Applied Behavior Analysis. 2005;38:349-357. [pmid: 16270844].
Dallery J, Glenn IM, Raiff BR. An Internet-based abstinence reinforcement treatment for cigarette smoking. Drug and Alcohol Dependence. 2007;86:230-238. [pmid: 16930854].
Dallery J, Raiff BR. Contingency management in the 21st century: Technological innovations to promote smoking cessation. Substance Use & Misuse. 2011;46:10-22. [pmid: 21190402].
Danaher BG, Lichtenstein E, McKay GH, Seeley RJ. Use of non-assigned smoking cessation programs among participants of a Web-based randomized controlled trial. Journal of Medical Internet Research. 2009;11:e26. [pmid: 19632976].
Danaher BG, McKay HG, Seeley JR. The information architecture of behavior change Websites. Journal of Medical Internet Research. 2005;7:e12. [pmid: 15914459].
Danaher BG, Seeley JR. Methodological issues in research on Web-based behavioral interventions. Annals of Behavioral Medicine. 2009;38:28-39. [pmid: 19806416].
Danaher BG, Smolkowski K, Seeley JR, Severson HH. Mediators of a successful Web-based smokeless tobacco cessation program. Addiction. 2008;103:1706-1712. [pmid: 18715238].
Daniels MH, Tyler JM, Christie BS. On-line instruction in counselor education: Possibilities, implications, and guidelines. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:303-317. Alexandria, VA. American Counseling Association.
Dausch BM, Miklowitz DJ, Nagamoto HT, Adler LE, Shore JH. Family-focused therapy via videoconferencing. Journal of Telemedicine and Telecare. 2009;15:211-214. [pmid: 19471035].
David AS, Chis, S I, Zavarei H. Effect of video self-observations vs. observations of others on insight in psychotic disorders. Journal of Nervous and Mental Disease. 2012;200:358-361. [pmid: 22456591].
Davies SF. A hospital driven telepsychiatry initiative to improve patient care and reduce costs. North Carolina Medical Journal. 2012;73:228-230. [pmid: 22779163].
Davis RA. A cognitive-behavioral model of pathological Internet use. Computers in Human Behavior. 2001;17:187-195.
Day SX, Schneider P. The subjective experiences of therapists in face-to-face, video, and audio sessions. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:203-218. Alexandria, VA. American Counseling Association.
Day SX, Schneider PL. Psychotherapy using distance technology: A comparison of face-to-face, video, and audio treatment. Journal of Counseling Psychology. 2002;49:499-503.
de Graaf LE, Gerhards SAH, Arntz A, Riper H, Metsemakers JFM, Evers SM, Huibers MJ. Clinical effectiveness on online computerised cognitive-behavioural therapy without support for depression in primary care: Randomised trial. British Journal of Psychiatry. 2009;195:73-80. [pmid: 19567900].
de Graaf LE, Gerhards SAH, Arntz A, Riper H, Metsemakers JFM, Evers SM, Huibers MJ. One-year follow-up results of unsupported online computerized cognitive behavioural therapy for depression in primary care: A randomized trial. Journal of Behavior Therapy and Experimental Psychiatry. 2011;42:89-95. [pmid: 20723885].
de Graaf LE, Hollon SD, Huibers MJ. Predicting outcome in computerized cognitive behavioral therapy for depression in primary care: A randomized trial. Journal of Consulting and Clinical Psychology. 2010;78:184-189. [pmid: 20350029].
De Las Cuevas C, Arredondo MT, Cabrera MF, Sulzenbacher H, Meise U. Randomized clinical trial of telepsychiatry through videoconference versus face-to-face conventional psychiatric treatment. Telemedicine Journal and e-Health. 2006;12:341-350. [pmid: 16796502].
Dear BF, Titov N, Schwencke G, Andrews G, Johnston L, Craske MG, McEvoy P. An open trial of a brief transdiagnostic Internet treatment for anxiety and depression. Behaviour Research and Therapy. 2011;49:830-837. [pmid: 21993153].
Deegan PE. The lived experience of using psychiatric medication in the recovery process and a shared decision-making program to support it. Psychiatric Rehabilitation Journal. 2007;31:62-69. [pmid: 17694717].
Deen TL, Bridges AJ, McGahan TC, Andrews AR III. Cognitive appraisals of specialty mental health services and their relation to mental health service utilization in the rural population. Journal of Rural Health. 2012;28:142-151. [pmid: 22458315].
Deen TL, Fortney JC, Pyne JM. Relationship between satisfaction, patient-centered care, adherence and outcomes among patients in a collaborative care trial for depression. Administration and Policy in Mental Health. 2011;38:345-355. [pmid: 20978932].
DeGuzman MA, Ross MW. Assessing the application of HIV and AIDS related education and counselling on the Internet. Patient Education and Counseling. 1999;36:209-228. [pmid: 14528557].
Deitz DK, Cook RF, Billings DW, Hendrickson A. A Web-based mental health program: Reaching parents at work. Journal of Pediatric Psychology. 2009;34:488-494. [pmid: 18845585].
Delespaul P, deVries M, van Os J. Determinants of occurrence and recovery from hallucinations in daily life. Social Psychiatry and Psychiatric Epidemiology. 2002;37:97-104. [pmid: 11990012].
Delrahim-Howlett K, Chambers CD, Clapp JD, Xu R, Duke K, Moyer RJ III, Van Sickle D. Web-based assessment and brief intervention for alcohol use in women of childbearing potential: A report of the primary findings. Alcoholism: Clinical and Experimental Research. 2011;35:1331-1338.
Demaso DR, Marcus NE, Kinnamon C, Gonzalez-Heydrich J. Depression experience journal: A computer-based intervention for families facing childhood depression. Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45:158-165. [pmid: 16429086].
Dennis M, Scott CK, Funk R. An experimental evaluation of recovery management checkups (RMC) for people with chronic substance use disorders. Evaluation and Program Planning. 2003;26:339-352.
Depp CA, Kim DH, de Dios LV, Wang V, Ceglowski J. A pilot study of mood ratings captured by mobile phone versus paper-and-pencil mood charts in bipolar disorder. Journal of Dual Diagnosis. 2012;8:326-332. [pmid: 23646035].
Derrig-Palumbo K. Using chat and instant messaging (IM) to conduct a therapeutic relationship. Anthony K, Nagel DM, Goss S, editors. The Use of technology in mental health: Applications, ethics and practice. 2010:15-28. Springfield, IL. Charles C. Thomas Publisher.
Des Jarlais DC, Paone D, Milliken J, Turner CF, Miller H, Gribble J, Friedman SR. Audio-computer interviewing to measure risk behaviour for HIV among injecting drug users: A quasi-randomised trial. The Lancet. 1999;353:1657-1661.
Detweiler MB, Arif S, Candelario J, Altman J, Murphy PF, Halling MH, Detweiler JG. Salem VAMC–U.S. Army Fort Bragg Warrior Transition Clinic telepsychiatry collaboration: 12-month operation clinical perspective. Telemedicine Journal and e-Health. 2012;18:81-86. [pmid: 22283361].
Devineni T, Blanchard EB. A randomized controlled trial of an Internet-based treatment for chronic headache. Behaviour Research and Therapy. 2005;43:277-292. [pmid: 15680926].
Dew MA, Goycoolea JM, Harris RC, Lee A, Zomak R, Dunbar-Jacob J, Kormos RL. An Internet-based intervention to improve psychosocial outcomes in heart transplant recipients and family caregivers: Development and evaluation. Journal of Heart and Lung Transplantation. 2004;23:745-758. [pmid: 15366436].
Dias K. The ana sanctuary: Women's pro-anorexic narratives in cyberspace. The body reader: Essential social and cultural readings. 2010:399-412. New York. New York University Press.
Difede J, Cukor J, Jayasinghe N, Patt I, Jedel S, Spielman L, Hoffman HG. Virtual reality exposure therapy for the treatment of posttraumatic stress disorder following September 11, 2001. Journal of Clinical Psychiatry. 2007;68:1639-1647. [pmid: 18052556].
Difede J, Cukor J, Patt I, Giosan C, Hoffman H. The application of virtual reality to the treatment of PTSD following the WTC attack. Annals of the New York Academy of Sciences. 2006;1071:500-501. [pmid: 16891607].
Di Noia J, Schwinn TM, Dastur ZA, Schinke SP. The relative efficacy of pamphlets, CD-ROM, and the Internet for disseminating adolescent drug abuse prevention programs: An exploratory study. Preventive Medicine. 2003;37:646-653. [pmid: 14636798].
Dixon BE, Hook JM, McGowan JJ. 2008. Using telehealth to improve quality and safety: Findings from the AHRQ portfolio. AHRQ Publication No. 09-0012-EF. Rockville, MD. Agency for Healthcare Research and Quality, U.S. Department of Health and Human Services.
Doebbeling BN, Chou AF, Tierney WM. Priorities and strategies for the implementation of integrated informatics and communications technology to improve evidence-based practice. Journal of General Internal Medicine. 2006;21:S50-S57. [pmid: 16637961].
Dolan D. New guideline for treating psychiatric disorders in multiple sclerosis. Neurology Now. 2014;10(1):12-14.
Dollar KM, Mix JM, Kozlowski LT. Little cigars, big cigars: Omissions and commissions of harm and harm reduction information on the Internet. Nicotine and Tobacco Research. 2008;10:819-826. [pmid: 18569755].
Dominick SA, Irvine AB, Beauchamp N, Seeley JR, Nolen-Hoeksema S, Doka KJ, Bonanno GA. An Internet tool to normalize grief. Omega (Westport). 2009;60:71-87. [pmid: 20039532].
Donker T, van Straten A, Marks I, Cuijpers P. A brief Web-based screening questionnaire for common mental disorders: Development and validation. Journal of Medical Internet Research. 2009;11:e19. [pmid: 19632977].
Donovan E, Wood M, Frayjo K, Black RA, Surette DA. A randomized, controlled trial to test the efficacy of an online, parent-based intervention for reducing the risks associated with college-student alcohol use. Addictive Behaviors. 2012;37:25-35. [pmid: 21963316].
Dorstyn DS, Mathias JL, Denson LA. Psychosocial outcomes of telephone-based counseling for adults with an acquired physical disability: A meta-analysis. Rehabilitation Psychology. 2011;56:1-14. [pmid: 21401281].
Doshi A, Patrick K, Sallis JF, Calfas K. Evaluation of physical activity Web sites for use of behavior change theories. Annals of Behavioral Medicine. 2003;25:105-111. [pmid: 12704012].
Doumas DM, Andersen LL. Reducing alcohol use in first-year university students: Evaluation of a Web-based personalized feedback program. Journal of College Counseling. 2009;12:18-32.
Doumas DM, Kane CM, Navarro B, Roman J. Decreasing heavy drinking in first-year students: Evaluation of a Web-based personalized feedback program administered during orientation. Journal of College Counseling. 2011;14:5-20.
Doumas DM, McKinley LL, Book P. Evaluation of two Web-based alcohol interventions for mandated college students. Journal of Substance Abuse Treatment. 2009;36:65-74. [pmid: 18657941].
Downer SR, Meara JG, Da Costa AC, Sethuraman K. SMS text messaging improves outpatient attendance. Australian Health Review. 2006;30:389-396. [pmid: 16879098].
Doyle AC, Goldschmidt A, Huang C, Winzelberg AJ, Taylor CB, Wilfley DE. Reduction of overweight and eating disorder symptoms via the Internet in adolescents: A randomized controlled trial. Journal of Adolescent Health. 2008;43:172-179. [pmid: 18639791].
Drake RE, Bond GR. Information technology and evidence-based practices: A commentary on “Evidence-based implementation strategies: Results of a qualitative study”. Community Mental Health Journal. 2008;44:225-226.
Drake RE, Bond GR. Implementing integrated mental health and substance abuse services. Journal of Dual Diagnosis. 2010;6:251-262.
Drake RE, Bond GR, Essock SM. Implementing evidence-based practices for people with schizophrenia. Schizophrenia Bulletin. 2009;35:704-713. [pmid: 19491315].
Draper J. Preventing suicide minute by minute. Behavioral Healthcare. 2007;27:29-31. [pmid: 18020178].
Draper M, Rees CS, Nathan PR. Internet-based self-management of generalised anxiety disorder: A preliminary study. Behaviour Change. 2008;25:229-244.
Driggs GE. The Internet as the road to better outcomes. Behavioral Health Management. 2000;20:20-24.
Du YS, Jiang W, Vance A. Longer term effect of randomized, controlled group cognitive behavioural therapy for Internet addiction in adolescent students in Shanghai. Australian and New Zealand Journal of Psychiatry. 2010;44:129-134. [pmid: 20113301].
DuBenske LL, Gustafson DH, Shaw BR, Cleary JF. Web-based cancer communication and decision making systems: Connecting patients, caregivers, and clinicians for improved health outcomes. Medical Decision Making. 2010;30:732-744. [pmid: 21041539].
DuBois D. Clinical and demographic features of the online counselling client population. Counselling and Psychotherapy Research. 2004;4:18-22.
Duggan M, Ellison NB, Lampe C, Lenhart A, Madden M. 2015. Social media update 2014. Washington, DC. Pew Research Center.
DuHamel KN, Mosher CE, Winkel G, Labay LE, Rini C, Meschian YM, Redd WH. Randomized clinical trial of telephone-administered cognitive–behavioral therapy to reduce post-traumatic stress disorder and distress symptoms after hematopoietic stem-cell transplantation. Journal of Clinical Oncology. 2010;28:3754-3761. [pmid: 20625129].
Dulin PL, Gonzalez VW, Campbell K. Results of a pilot test of a self-administered smartphone-based treatment system for alcohol use disorders: Usability and early outcomes. Substance Abuse. 2014;35(2):168-175. [pmid: 24821354].
Dutta-Bergman MJ. Health attitudes, health cognitions, and health behaviors among Internet health information seekers: Population-based survey. Journal of Medical Internet Research. 2004;6:e15. [pmid: 15249264].
Dutta-Bergman MJ. Media use theory and Internet use for health care. Murero M, editor. The Internet and health care: Theory, research, and practice. 2006:83-103. Mahwah, NJ. Lawrence Erlbaum Associates Publishers.
Dwight JM, Apesoa-Varano C, Hay J, Unutzer J, Hinton L. Depression treatment preferences of older white and Mexican origin men. General Hospital Psychiatry. 2012;35(1):59-65. [pmid: 23141027].
Dwolatzky T, Dimant L, Simon ES, Doniger GM. Validity of a short computerized assessment battery for moderate cognitive impairment and dementia. International Psychogeriatrics. 2010;22:795-803. [pmid: 20519066].
Dyer KA, Thompson CD. Internet use for Web-education on the overlooked areas of grief and loss. CyberPsychology and Behavior. 2000;3:255-270.
Eakin EG, Lawler SP, Vandelanotte C, Owen N. Telephone interventions for physical activity and dietary behavior change: A systematic review. American Journal of Preventive Medicine. 2007;32:419-434. [pmid: 17478269].
Ebner-Priemer UW, Trull TJ. Ecological momentary assessment of mood disorders and mood dysregulation. Psychological Assessment. 2009;21:463-475. [pmid: 19947781].
Edwards CC, Elliott SP, Conway TL, Woodruff SI. Teen smoking cessation help via the Internet: A survey of search engines. Health Promotion Practice. 2003;4:262-265. [pmid: 14610996].
Efstathiou G. Students' psychological Web consulting: Function and outcome evaluation. British Journal of Guidance and Counselling. 2009;37:243-255.
Egan J, Casadonte P, Gartenmann T, Martin J, McCance-Katz E, Netherland J, Fiellen DA. The Physician Clinical Support System-Buprenorphine (PCSS-B): A novel project to expand/improve buprenorphine treatment. Journal of General Internal Medicine. 2010;25:936-941. [pmid: 20458550].
Egan J, Chenoweth L, McAuliffe D. Email-facilitated qualitative interviews with traumatic brain injury survivors: A new and accessible method. Brain Injury. 2006;20:1283-1294. [pmid: 17132551].
Egan J, Worrall L, Oxenham D. An Internet training intervention for people with traumatic brain injury: Barriers and outcomes. Brain Injury. 2005;19:555-568. [pmid: 16175810].
Egede LE, Frueh CB, Richardson LK, Acierno R, Mauldin PD, Knapp RG, Lejuez C. Rationale and design: Telepsychology service delivery for depressed elderly veterans. Trials. 2009;10.
Ehrenreich B, Righter B, Rocke DA, Dixon L, Himelhoch S. Are mobile phones and handheld computers being used to enhance delivery of psychiatric treatment? A systematic review. Journal of Nervous and Mental Disease. 2011;199:886-891. [pmid: 22048142].
Eichhorn KC. Soliciting and providing social support over the Internet: An investigation of online eating disorder support groups. Journal of Computer-Mediated Communication. 2008;14:67-78.
Eisdorfer C, Czaja SJ, Loewenstein DA, Rubert MP, Argüelles S, Mitrani VB, Szapocznik J. The effect of a family therapy and technology-based intervention on caregiver depression. The Gerontologist. 2003;43:521-531. [pmid: 12937331].
Ekberg J, Timpka T, Bang M, Froberg A, Halje K, Eriksson H. Cell phone-supported cognitive behavioural therapy for anxiety disorders: A protocol for effectiveness studies in frontline settings. BMC Medical Research Methodology. 2011;11:3. [pmid: 21219593].
Elenko E, Speier A, Zohar D. A regulatory framework emerges for digital medicine. Nature Biotechnology. 2015;33:697-702.
Elieson MV, Rubin LJ. Differentiation of self and major depressive disorders: A test of Bowen theory among clinical, traditional, and Internet groups. Family Therapy. 2001;28:125-142.
Elleven RK, Allen J. Applying technology to online counseling: Suggestions for the beginning e-therapist. Journal of Instructional Psychology. 2004;31:223-227.
Elliott JC, Carey KB, Bolles JR. Computer-based interventions for college drinking: A qualitative review. Addictive Behaviors. 2008;33:994-1005. [pmid: 18538484].
Elliott SP, Edwards CC, Woodruff SI, Conway TL. On-line smoking cessation: What's porn got to do with it?. Tobacco Control. 2001;10:397. [pmid: 11806353].
Ellis AR, Konrad TR, Thomas KC, Morrissey JP. County-level estimates of mental health professional supply in the United States. Psychiatric Services. 2009;60:1315-1322. [pmid: 19797370].
Ellis DG, Mayrose J. The success of emergency telemedicine at the State University of New York at Buffalo. Telemedicine Journal and e-Health. 2003;9:73-79.
Emmelkamp PM. Technological innovations in clinical assessment and psychotherapy. Psychotherapy and Psychosomatics. 2005;74:336-343. [pmid: 16244509].
Emmelkamp PM. Virtual reality in psychotherapy. Psychological Medicine. 2005;34:9-17.
Emmelkamp PM. Attention bias modification: The emperor's new suit?. BMC Medicine. 2012;10:63. [pmid: 22731990].
Engel SG, Wonderlich SA. New technologies in treatments for eating disorders. Grilo CM, Mitchell JE, editors. The treatment of eating disorders: A clinical handbook. 2010:500-509. New York. Guilford Press.
Enos G. Technology (online virtual platforms such as Second Life could help clients model recovery-affirming behaviors). Addiction Professional. 2008;6:53-54.
Ens CDL, Chochinov HM, Berard JLM, Harlos MS, Stenekes SJ, Wowchuk SM. Pediatric palliative care online: The views of health care professionals. Journal of Palliative Care. 2008;24:41-48. [pmid: 18459596].
Enwald KHP, Huotari AM-L. Preventing the obesity epidemic by second generation tailored health communication: An interdisciplinary review. Journal of Medical Internet Research. 2010;12:e24. [pmid: 20584698].
Eonta AM, Christon LM, Hourigan SE, Ravindran N, Vrana SR, Southam-Gerow MA. Using everyday technology to enhance evidence-based treatments. Professional Psychology: Research and Practice. 2011;42:513-520.
Erdman HP, Klein MH, Greist JH. Direct patient computer interviewing. Journal of Consulting and Clinical Psychology. 1985;53:760-773. [pmid: 3841354].
Ernst E. Serious psychiatric and neurological adverse effects of herbal medicines—A systematic review. Acta Psychiatrica Scandinavica. 2003;108:83-91. [pmid: 12823164].
Ertin E, Stohs N, Kumar S, Raij A, al'Absi M, Shah S. AutoSense: Unobtrusively wearable sensor suite for inferring the onset, causality, and consequences of stress in the field. Proceedings of the 9th ACM Conference on Embedded Networked Sensor Systems. 2011:274-287. New York. Association for Computing Machinery.
Erwin BA, Turk CL, Heimberg RG, Fresco DM, Hantula DA. The Internet: Home to a severe population of individuals with social anxiety disorder?. Journal of Anxiety Disorders. 2004;18:629-646. [pmid: 15275943].
Escoffery C, McCormick L, Bateman K. Development and process evaluation of a Web-based smoking cessation program for college smokers: Innovative tool for education. Patient Education and Counseling. 2004;53:217-225. [pmid: 15140462].
Escudero V, Friedlander ML, Heatherington L. Using the e-SOFTA for video training and research on alliance-related behavior. Psychotherapy. 2011;48:138-147. [pmid: 21639657].
Espie CA, Kyle SD, Williams C, Ong JC, Douglas NJ, Hames P, Brown JS. A randomized, placebo-controlled trial of online cognitive behavioral therapy for chronic insomnia disorder delivered via an automated media-rich Web application. Sleep. 2012;35:769-781. [pmid: 22654196].
Etter JF. Comparing the efficacy of two Internet-based, computer-tailored smoking cessation programs: A randomized trial. Journal of Medical Internet Research. 2005;7:e2. [pmid: 15829474].
Etter JF. The Internet and the industrial revolution in smoking cessation counselling. Drug and Alcohol Review. 2006;25:79-84. [pmid: 16492580].
Etter JF. A list of the most popular smoking cessation Web sites and a comparison of their quality. Nicotine and Tobacco Research. 2006;8(Suppl 1):S27-S34. [pmid: 17491168].
Etter JF. Comparing computer-tailored, Internet-based smoking cessation counseling reports with generic, untailored reports: A randomized trial. Journal of Health Communication. 2009;14:646-657. [pmid: 19851916].
Etter JF, Le Houezec J, Huguelet P, Etter M. Testing the Cigarette Dependence Scale in 4 samples of daily smokers: Psychiatric clinics, smoking cessation clinics, a smoking cessation Website and in the general population. Addictive Behaviors. 2009;34:446-450. [pmid: 19157716].
Evers KE, Prochaska JM, Prochaska JO, Driskell MM, Cummins CO, Velicer WF. Strengths and weaknesses of health behavior change programs on the Internet. Journal of Health Psychology. 2003;8:63-70. [pmid: 22113901].
Eyrich-Garg KM. Mobile phone technology: A new paradigm for the prevention, treatment, and research of the non-sheltered “street” homeless?. Journal of Urban Health. 2010;87:365-380. [pmid: 20397058].
Eysenbach G, Powell J, Englesakis M, Rizo C, Stern A. Health related virtual communities and electronic support groups: Systematic review of the effects of online peer to peer interactions. BMJ. 2004;328:1166. [pmid: 15142921].
Facebook. 2015. Stats—Facebook newsroom. Retrieved June 24, 2015 from: http://newsroom.fb.com/company-info.
Farabee D, Cousins SJ, Brecht ML, Antonini VP, Lee AB, Brummer J, Rawson RA. A comparison of four telephone-based counseling styles for recovering stimulant users. Psychology of Addictive Behaviors. 2012;27(1):223-229. [pmid: 22867295].
Farrell SP, Mahone IH, Guilbaud P. Web technology for persons with serious mental illness. Archives of Psychiatric Nursing. 2004;18:121-125. [pmid: 15305277].
Farrer L, Christensen H, Griffiths KM, Mackinnon A. Internet-based CBT for depression with and without telephone tracking in a national helpline: Randomised controlled trial. PLOS ONE. 2011;6:e28099. [pmid: 22140514].
Farvolden P, Cunningham J, Selby P. Using e-health programs to overcome barriers to the effective treatment of mental health and addiction problems. Journal of Technology in Human Services. 2009;27:5-22.
Farvolden P, Denisoff E, Selby P, Bagby RM, Rudy L. Usage and longitudinal effectiveness of a Web-based self-help cognitive behavioral therapy program for panic disorder. Journal of Medical Internet Research. 2005;7:e7. [pmid: 15829479].
Farvolden P, McBride C, Bagby RM, Ravitz P. A Web-based screening instrument for depression and anxiety disorders in primary care. Journal of Medical Internet Research. 2003;5:e23. [pmid: 14517114].
Favela J, Tentori M, Gonzalez VM. Ecological validity and pervasiveness in the evaluation of ubiquitous computing technologies for health care. International Journal of Human Computer Interaction. 2010;26:414-444.
Federal Communications Commission. 2015. FCC Chairman Wheeler seeks comment on modernizing lifeline to make 21st century broadband affordable for low-income households. Washington DC. Federal Communications Commission.
Feil EG, Noell J, Lichtenstein E, Boles SM, McKay HG. Evaluation of an Internet-based smoking cessation program: Lessons learned from a pilot study. Nicotine and Tobacco Research. 2003;5:189-194. [pmid: 12745491].
Feldman MD. Munchausen by Internet: Detecting factitious illness and crisis on the Internet. Southern Medical Journal. 2000;93:669-672. [pmid: 10923952].
Feldman S. Choices and challenges. Managed behavioral health services: Perspectives and practice. 2003:3-23. Springfield, IL. Charles C. Thomas Publisher.
Fenichel M. The supervisory relationship online. Goss S, Anthony K, editors. Technology in counselling and psychotherapy: A practitioner's guide. 2003:75-89. Houndmills, United Kingdom. Palgrave Macmillan.
Fenichel M. Online behavior, communication, and experience. Kraus R, Zack J, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:3-18. New York. Elsevier Science.
Fenichel M. 2009. The here and now of cyberspace. Retrieved June 29, 2014 from: http://www.fenichel.com/herenow.shtml.
Fenichel M. 2009. Online psychotherapy: Technical difficulties, formulations and processes. Retrieved June 29, 2014 from: http://www.fenichel.com/technical.shtml.
Fenichel M, Suler J, Barak A, Zelvin E, Jones G, Munro K, Walker-Schmucker W. Myths and realities of online clinical work. CyberPsychology and Behavior. 2002;5:481-497. [pmid: 12448785].
Ferguson SG, Shiffman S. Using the methods of ecological momentary assessment in substance dependence research–Smoking cessation as a case study. Substance Use & Misuse. 2011;46:87-95. [pmid: 21190409].
Fernández-Aranda F, Nunez A, Martinez C, Krug I, Cappozzo M, Carrard I, Lam T. Internet-based cognitive–behavioral therapy for bulimia nervosa: A controlled study. CyberPsychology and Behavior. 2009;12:37-41. [pmid: 19006463].
Ferreira CJ. 2005. Effectiveness of teaching basic microskills and empathy development in an online environment. Virginia Beach, VA. Regent University.
Ferrer-García M, Gutiérrez-Maldonado J. The use of virtual reality in the study, assessment, and treatment of body image in eating disorders and nonclinical samples: A review of the literature. Body Image. 2012;9:1-11. [pmid: 22119329].
Ferron JC, Brunette MF, McGurk SR, Xie H, Frounfelker R, Cook JA, McHugo G. Do symptoms and cognitive problems affect the use and efficacy of a Web-based decision support system for smokers with serious mental illness?. Journal of Dual Diagnosis. 2012;8:315-325.
Fichter MM, Quadflieg N, Nisslmuller K, Lindner S, Osen B, Huber T, Wünsch-Leiteritz W. Does Internet-based prevention reduce the risk of relapse for anorexia nervosa?. Behaviour Research and Therapy. 2012;50:180-190. [pmid: 22317754].
Finfgeld DL. Psychotherapy in cyberspace. Journal of the American Psychiatric Nurses Association. 1999;5:105-110.
Finfgeld DL. Therapeutic groups online: The good, the bad, and the unknown. Issues in Mental Health Nursing. 2000;21:241-255. [pmid: 11075065].
Finfgeld-Connett D. Web-based treatment for problem drinking. Journal of Psychosocial Nursing and Mental Health Services. 2006;44:20-27. [pmid: 16989328].
Finfgeld-Connett D. Web-based treatment for rural women with alcohol problems: Preliminary findings. Computers Informatics Nursing. 2009;27:345-353.
Finfgeld-Connett D, Madsen R. Web-based treatment of alcohol problems among rural women: Results of a randomized pilot investigation. Journal of Psychosocial Nursing and Mental Health Services. 2008;46:46-53. [pmid: 18823000].
Fink A, Elliott MN, Tsai M, Beck JC. An evaluation of an intervention to assist primary care physicians in screening and educating older patients who use alcohol. Journal of the American Geriatrics Society. 2005;53:1937-1943. [pmid: 16274375].
Finkel S, Czaja SJ, Schulz R, Martinovich Z, Harris C, Pezzuto D. E-care: A telecommunications technology intervention for family caregivers of dementia patients. The American Journal of Geriatric Psychiatry. 2007;15:443-448. [pmid: 17463195].
Finkelstein J, Lapshin O. Reducing depression stigma using a Web-based program. International Journal of Medical Informatics. 2007;76:726-734. [pmid: 16996299].
Finkelstein J, Lapshin O, Cha E. Feasibility of promoting smoking cessation among methadone users using multimedia computer-assisted education. Journal of Medical Internet Research. 2008;10:e33. [pmid: 18984556].
Finn J. MSW student perceptions of the efficacy and ethics of Internet-based therapy. Journal of Social Work Education. 2002;38:403-419.
Finn J, Banach M. Victimization online: The down side of seeking human services for women on the Internet. CyberPsychology & Behavior. 2000;3:243-254.
Finn J, Bruce S. The LivePerson model for delivery of etherapy services: A case study. Journal of Technology in Human Services. 2008;26:282-309.
Finn J, Hughes P. Evaluation of the RAINN National Sexual Assault Online Hotline. Journal of Technology in Human Services. 2008;26:203-222.
Fiore MC, Bailey WC, Cohen SJ. 2000. Treating tobacco use and dependence: Clinical practice guideline. Washington DC. Office of the Surgeon General.
Fisher CB, Fried AL. Internet-mediated psychological services and the American Telemedicine Association Ethics Code. Psychotherapy: Theory, Research, Practice, Training. 2003;40:103-111.
Fitzgerald JL, Mulford HA. An experimental test of telephone aftercare contacts with alcoholics. Journal of Studies on Alcohol. 1985;46:418-424. [pmid: 2999514].
Fjeldsoe BS, Marshall AL, Miller YD. Behavior change interventions delivered by mobile telephone short-message service. American Journal of Preventive Medicine. 2009;36:165-173. [pmid: 19135907].
Fletcher-Tomenius LJ, Vossler A. Trust in online therapeutic relationships: The therapist's experience. Counselling Psychology Review. 2009;24:24-33.
Foley L, Maddison R. Use of active video games to increase physical activity in children: A (virtual) reality?. Pediatric Exercise Science. 2010;22:7-20. [pmid: 20332536].
Forbey JD, Ben-Porath YS. Computerized adaptive personality testing: A review and illustration with the MMPI-2 computerized adaptive version. Psychological Assessment. 2007;19:14-24. [pmid: 17371120].
Forducey PG, Glueckauf RL, Bergquist TF, Maheu MM, Yutsis M. Telehealth for persons with severe functional disabilities and their caregivers: Facilitating self-care management in the home setting. Psychological Services. 2012;9:144-162. [pmid: 22662729].
Forman R, Crits-Christoph P, Kaynak O, Worley M, Hantula DA, Kulaga A, Cawley M. A feasibility study of a Web-based performance improvement system for substance abuse treatment providers. Journal of Substance Abuse Treatment. 2007;33:363-371. [pmid: 17499954].
Fortney JC, Maciejewski ML, Tripathi SP, Deen TL, Pyne JM. A budget impact analysis of telemedicine-based collaborative care for depression. Medical Care. 2011;49:872-880. [pmid: 21623240].
Fox NJ, Ward K, O'Rourke A. Pro-anorexia, weight-loss drugs and the Internet: An “anti-recovery” explanatory model of anorexia. Sociology of Health and Illness. 2005;27:944-971. [pmid: 16313524].
Fox NJ, Ward KJ, O'Rourke AJ. The ‘expert patient’: Empowerment or medical dominance? The case of weight loss, pharmaceutical drugs and the Internet. Social Science and Medicine. 2005;60:1209-1309. [pmid: 15626518].
Fox S, Duggan M. 2012. Mobile health 2012: Half of smartphone owners use their devices to get health information and one–fifth of smartphone owners have health apps. Washington, DC. Pew Research Center's Internet & American Life Project.
Frame MW. The ethics of counseling via the Internet. Family Journal. 1997;5:328-330.
Frangou S, Sachpazidis I, Stassinakis A, Sakas G. Telemonitoring of medication adherence in patients with schizophrenia. Telemedicine Journal and e-Health. 2005;11:675-683. [pmid: 16430387].
Frank B, Dewart T, Schmeidler J, Demirjian A. The impact of 9/11 on New York City's substance abuse treatment programs: A study of program administrators. Journal of Addictive Diseases. 2006;25:5-14. [pmid: 16597568].
Franklin PD, Rosenbaum PF, Carey MP, Roizen MF. Using sequential e-mail messages to promote health behaviors: Evidence of feasibility and reach in a worksite sample. Journal of Medical Internet Research. 2006;8:e3. [pmid: 16585028].
Franklin V, Waller A, Pagliari C, Greene S. “Sweet Talk”: Text messaging support for intensive insulin therapy for young people with diabetes. Diabetes Technology and Therapeutics. 2003;5:991-996. [pmid: 14709202].
Franklin V, Waller A, Pagliari C, Greene S. A randomized controlled trial of Sweet Talk, a text-messaging system to support young people with diabetes. Diabetic Medicine. 2006;23:1332-1338. [pmid: 17116184].
Franko DL, Mintz LB, Villapiano M, Green TC, Mainelli D, Folensbee L, Budman SH. Food, mood, and attitude: Reducing risk for eating disorders in college women. Health Psychology. 2005;24:567-578. [pmid: 16287402].
Fraser T, McRobbie H, Bullen C, Whittaker R, Barlow D. Acceptability and outcome of an Internet-based smoking cessation programme. International Journal of Tuberculosis and Lung Disease. 2010;14:113-118. [pmid: 20003704].
Freddolino PP, Blaschke CM. Therapeutic applications of online gaming. Journal of Technology in Human Services. 2008;26:423-446.
Free C, Knight R, Robertson S, Whittaker R, Edwards P, Zhou W, Roberts I. Smoking cessation support delivered via mobile phone text messaging (txt2stop): A single-blind, randomised trial. The Lancet. 2011;378:49-55.
Free C, Whittaker R, Knight R, Abramsky T, Rodgers A, Roberts IG. Txt2stop: A pilot randomised controlled trial of mobile phone-based smoking cessation support. Tobacco Control. 2009;18:88-91. [pmid: 19318534].
Freedman MJ, Lester KM, McNamara C, Milby JB, Schumacher JE. Cell phones for ecological momentary assessment with cocaine-addicted homeless patients in treatment. Journal of Substance Abuse Treatment. 2006;30:105-111. [pmid: 16490673].
Fridrici M, Lohaus A. Stress-prevention in secondary schools: Online versus face-to face training. Health Education. 2009;109:299-313.
Fridrici M, Lohaus A, Glass C. Effects of incentives in Web-based prevention for adolescents: Results of an exploratory field study. Psychology and Health. 2009;24:663-675. [pmid: 20205019].
Frueh BC, Henderson S, Myrick H. Telehealth service delivery for persons with alcoholism. Journal of Telemedicine and Telecare. 2005;11:372-375. [pmid: 16238840].
Frueh BC, Monnier J, Grubaugh AL, Elhai JD, Yim E, Knapp R. Therapist adherence and competence with manualized cognitive-behavioral therapy for PTSD delivered via videoconferencing technology. Behavior Modification. 2007;31:856-866. [pmid: 17932240].
Frueh BC, Monnier J, Yim E, Grubaugh AL, Hamner MB, Knapp RG. A randomized trial of telepsychiatry for post-traumatic stress disorder. Journal of Telemedicine and Telecare. 2007;13:142-147. [pmid: 17519056].
Fukkink RG, Hermanns JM. Children's experiences with chat support and telephone support. Journal of Child Psychology and Psychiatry. 2009;50:759-766. [pmid: 19207634].
Fukkink RG, Hermanns JM. Counseling children at a helpline: Chatting or calling?. Journal of Community Psychology. 2009;37:939-948.
Funderburk BW, Ware LM, Altshuler E, Chaffin M. Use and feasibility of telemedicine technology in the dissemination of parent–child interaction therapy. Child Maltreatment. 2008;13:377-382. [pmid: 18843144].
Fung DSS, Manassis K, Kenny A, Fiksenbaum L. Web-based CBT for selective mutism. Journal of the American Academy of Child & Adolescent Psychiatry. 2002;41:112-113. [pmid: 11841064].
Funk LK, Stevens JV, Appel JL, Bauck A, Brantley JP, Champagne MC, Vollmer WM. Associations of Internet Website use with weight change in a long-term weight loss maintenance program. Journal of Medical Internet Research. 2010;12:e29. [pmid: 20663751].
Furmark T, Carlbring P, Hedman E, Sonnenstein A, Clevberger P, Bohman B, Andersson G. Guided and unguided self-help for social anxiety disorder: Randomised controlled trial. British Journal of Psychiatry. 2009;195:440-447. [pmid: 19880935].
Gabriele JM, Stewart TM, Sample A, Davis AB, Allen R, Martin CK, Williamson DA. Development of an Internet-based obesity prevention program for children. Journal of Diabetes Science and Technology. 2010;4:723-732. [pmid: 20513340].
Gaggioli A, Mantovani F, Castelnuovo G, Wiederhold B, Riva G. Avatars in clinical psychology: A framework for the clinical use of virtual humans. CyberPsychology and Behavior. 2003;6:117-125. [pmid: 12804023].
Gaggioli A, Riva G. A second life for telehealth?. Annual Review of CyberTherapy and Telemedicine. 2007;5:29-36.
Gainsbury S, Blaszczynski A. Online self-guided interventions for the treatment of problem gambling. International Gambling Studies. 2011;11:289-308.
Galanter M, Keller DS, Dermatis H. Using the Internet for clinical training: A course on network therapy for substance abuse. Psychiatric Services. 1997;48:999-1000. 1008. [pmid: 9255829].
Galanter M, Keller DS, Dermatis H, Biderman D. Use of the Internet for addiction education: Combining network therapy with pharmacotherapy. American Journal of Addiction. 1998;7:7-13.
Gammon D, Sorlie T, Bergvik S, Sorensen Hoifodt T. Psychotherapy supervision conducted via videoconferencing: A qualitative study of users' experiences. Nordic Journal of Psychiatry. 1998;52:411-421.
Garb HN. Computer-administered interviews and rating scales. Psychological Assessment. 2007;19:4-13. [pmid: 17371119].
García-Lizana F, Muñoz-Mayorga I. Telemedicine for depression: A systematic review. Perspectives in Psychiatric Care. 2010;46:119-126. [pmid: 20377799].
García-Lizana F, Muñoz-Mayorga I. What about telepsychiatry? A systematic review. Primary Care Companion to the Journal of Clinical Psychiatry. 2010;12(2).
Garnett JL, Kouzmin A. Communicating throughout Katrina: Competing and complementary conceptual lenses on crisis communication. Public Administration Review. 2007;67:171-188.
Gega L, Marks I, Mataix-Cols D. Computer-aided CBT self-help for anxiety and depressive disorders: Experience of a London clinic and future directions. Journal of Clinical Psychology. 2004;60:147-157. [pmid: 14724922].
Gelenberg AJ. Using assessment tools to screen for, diagnose, and treat major depressive disorder in clinical practice. Journal of Clinical Psychiatry. 2010;71(Suppl E1):e01. [pmid: 20371028].
Gelso CJ. Emerging and continuing trends in psychotherapy: Views from an editor's eye. Psychotherapy. 2011;48:182-187. [pmid: 21639662].
Genuis SJ, Genuis SK. Implications of cyberspace communication: A role for physicians. Southern Medical Journal. 2005;98:451-455. [pmid: 15898522].
George CF, Peveler RC, Heiliger S, Thompson C. Compliance with tricyclic antidepressants: The value of four different methods of assessment. British Journal of Clinical Pharmacology. 2000;50:166-171. [pmid: 10930969].
Geraghty AW, Wood AM, Hyland ME. Attrition from self-directed interventions: Investigating the relationship between psychological predictors, intervention content and dropout from a body dissatisfaction intervention. Social Science and Medicine. 2010;71:30-37. [pmid: 20400220].
Gerardi M, Cukor J, Difede J, Rizzo A, Rothbaum BO. Virtual reality exposure therapy for post-traumatic stress disorder and other anxiety disorders. Current Psychiatry Reports. 2010;12:298-305. [pmid: 20535592].
Geraty E. Harnessing technology—The cyber practice (the Internet and counseling). Counselor. 2002;3:43-44.
Gerber BS, Stolley MR, Thompson AL, Sharp LK, Fitzgibbon ML. Mobile phone text messaging to promote healthy behaviors and weight loss maintenance: A feasibility study. Health Informatics Journal. 2009;15:17-25. [pmid: 19218309].
Germain V, Marchand A, Bouchard S, Drouin MS, Guay S. Effectiveness of cognitive behavioural therapy administered by videoconference for posttraumatic stress disorder. Cognitive Behaviour Therapy. 2009;38:42-53. [pmid: 19235601].
Germain V, Marchand A, Bouchard S, Guay S, Drouin MS. Assessment of the therapeutic alliance in face-to-face or videoconference treatment for posttraumatic stress disorder. Cyberpsychology, Behavior, and Social Networking. 2010;13:29-35.
Gibbons MC. 2007. eHealth solutions for healthcare disparities. New York. Springer Publishing Co.
Gibbons MC, Fleisher L, Slamon RE, Bass S, Kandadai V, Beck JR. Exploring the potential of Web 2.0 to address health disparities. Journal of Health Communication. 2011;16(Suppl 1):77-89. [pmid: 21843097].
Gibbons RD, Weiss DJ, Kupfer DJ, Frank E, Fagiolini A, Grochocinski VJ, Immekus JC. Using computerized adaptive testing to reduce the burden of mental health assessment. Psychiatric Services. 2008;59:361-368. [pmid: 18378832].
Gibbs PL. Reality in cyberspace: Analysands' use of the Internet and ordinary everyday psychosis. Psychoanalytic Review. 2007;94:11-38. [pmid: 17367275].
Gibson JL, Pennington RC, Stenhoff DM, Hopper JS. Using desktop videoconferencing to deliver interventions to a preschool student with autism. Topics in Early Childhood Special Education. 2010;29:214-225.
Gibson SF, Morley S, Romeo-Wolff CP. A model community telepsychiatry program in rural Arizona. Hsiung RC, editor. E-therapy: Case studies, guiding principles, and the clinical potential of the Internet. 2002:69-91. New York. W. W. Norton & Co.
Gilat I, Shahar G. Emotional first aid for a suicide crisis: Comparison between telephonic hotline and Internet. Psychiatry: Interpersonal and Biological Processes. 2007;70:12-18.
Giles D. Constructing identities in cyberspace: The case of eating disorders. British Journal of Social Psychology. 2006;45:463-477. [pmid: 16984715].
Gillett J. Media activism and Internet use by people with HIV/AIDS. Sociology of Health and Illness. 2003;25:608-624. [pmid: 12919448].
Gilman M, Stensland J. Telehealth and Medicare: Payment policy, current use, and prospects for growth. Medicare & Medicaid Research. 2013;3(4):E1-E13.
Ginory A, Sabatier LM, Eth S. Addressing therapeutic boundaries in social networking. Psychiatry. 2012;75:40-48. [pmid: 22397540].
Gitlow S. The evolution of online treatment. Counselor. 2002;3:52-53.
Gitlow S. On the Web: The clinician-patient e-mail dilemma. Counselor. 2002;3:50-51.
Gitlow S. Web-based aftercare: The new choice. Counselor. 2002;4:65-66.
Gitlow S. On the Web: Patient–clinician e-mail: What are we securing?. Counselor. 2003;4:70-71.
Gitlow S. On the Web: Responsible telemedicine?. Counselor. 2003;4:46-47.
Gitlow S. What in the WWW will work for us? (World Wide Web). Counselor. 2004;5:73-74.
Glasgow RE. eHealth evaluation and dissemination research. American Journal of Preventive Medicine. 2007;32:S119-S126. [pmid: 17466816].
Glasgow RE. Enhancing the scientific foundation of Internet intervention research. Annals of Behavioral Medicine. 2009;38:46-47. [pmid: 19816749].
Glasgow RE, Bull SS, Piette JD, Steiner JF. Interactive behavior change technology: A partial solution to the competing demands of primary care. American Journal of Preventive Medicine. 2004;27:80-87. [pmid: 15275676].
Glasgow RE, Nelson CC, Kearney KA, Reid R, Ritzwoller DP, Strecher VJ, Wildenhaus K. Reach, engagement, and retention in an Internet-based weight loss program in a multi-site randomized controlled trial. Journal of Medical Internet Research. 2007;9:e11. [pmid: 17513282].
Glenn IM, Dallery J. Effects of Internet-based voucher reinforcement and a transdermal nicotine patch on cigarette smoking. Journal of Applied Behavior Analysis. 2007;40:1-13. [pmid: 17471790].
Glueckauf RL, Fritz SP, Ecklund-Johnson EP, Liss HJ, Dages P, Carney P. Videoconferencing-based family counseling for rural teenagers with epilepsy: Phase 1 findings. Rehabilitation Psychology. 2002;47:49-72.
Glueckauf RL, Lustria ML. E-health self-care interventions for persons with chronic illnesses: Review and future directions. Parker JC, Thorson E, editors. Health communication in the new media landscape. 2009:151-242. New York. Springer Publishing Co.
Glueckauf RL, Pickett TC, Ketterson TU, Loomis JS, Rozensky RH. Preparation for the delivery of telehealth services: A self-study framework for expansion of practice. Professional Psychology: Research and Practice. 2003;34:159-163.
Glynn SM, Randolph ET, Garrick T, Lui A. A proof of concept trial of an online psychoeducational program for relatives of both veterans and civilians living with schizophrenia. Psychiatric Rehabilitation Journal. 2010;33:278-287. [pmid: 20374986].
Godin S. Technology applications in prevention: An introduction. Journal of Prevention and Intervention in the Community. 2005;29:1-6.
Godleski L, Cervone D, Vogel D, Rooney M. Home telemental health implementation and outcomes using electronic messaging. Journal of Telemedicine and Telecare. 2012;18:17-19. [pmid: 22052966].
Godleski L, Nieves JE, Darkins A, Lehmann L. VA telemental health: Suicide assessment. Behavioral Sciences & the Law. 2008;26:271-286. [pmid: 18548515].
Goh DH, Ang RP, Tan HC. Strategies for designing effective psychotherapeutic gaming interventions for children and adolescents. Computers in Human Behavior. 2008;24:2217-2235.
Gold BC, Burke S, Pintauro S, Buzzell P, Harvey-Berino J. Weight loss on the Web: A pilot study comparing a structured behavioral intervention to a commercial program. Obesity (Silver Spring). 2007;15:155-164. [pmid: 17228043].
Golkaramnay V, Bauer S, Haug S, Wolf M, Kordy H. The exploration of the effectiveness of group therapy through an Internet chat as aftercare: A controlled naturalistic study. Psychotherapy and Psychosomatics. 2007;76:219-225. [pmid: 17570960].
Gollings EK, Paxton SJ. Comparison of Internet and face-to-face delivery of a group body image and disordered eating intervention for women: A pilot study. Eating Disorders: The Journal of Treatment and Prevention. 2006;14:1-15.
Goodwin MS, Velicer WF, Intille SS. Telemetric monitoring in the behavior sciences. Behavior Research Methods. 2008;40:328-341. [pmid: 18411557].
Gorini A, Fasano AI, Gaggioli A, Vigna C, Riva G. A second life for telehealth: Prospects for the use of virtual online worlds in clinical psychology. Annual Review of CyberTherapy and Telemedicine. 2008;6:13-19.
Goss S, Anthony K. 2003. Technology in counselling and psychotherapy: A practitioner's guide. Basingstoke, United Kingdom. Palgrave Macmillan.
Goss S, Anthony K. Developments in the use of technology in counselling and psychotherapy. British Journal of Guidance and Counselling. 2009;37:223-230.
Gotham HJ. Diffusion of mental health and substance abuse treatments: Development, dissemination, and implementation. Clinical Psychology: Science and Practice. 2004;11:161-176.
Goudsmit EM. Chronic fatigue syndrome. Irish Journal of Psychological Medicine. 2007;100:7.
Gould MS, Harris Munfakh JL, Kleinman M, Lake AM. National Suicide Prevention Lifeline: Enhancing mental health care for suicidal individuals and other people in crisis. Suicide and Life-Threatening Behavior. 2012;42:22-35. [pmid: 22320194].
Gould MS, Kalafat J, Harris Munfakh JL, Kleinman M. An evaluation of crisis hotline outcomes. Part 2: Suicidal callers. Suicide and Life-Threatening Behavior. 2007;37:338-352. [pmid: 17579545].
Gowen K, Deschaine M, Gruttadara D, Markey D. Young adults with mental health conditions and social networking Websites: Seeking tools to build community. Psychiatric Rehabilitation Journal. 2012;35:245-250. [pmid: 22246123].
Grady B, Singleton M. Telepsychiatry “coverage” to a rural inpatient psychiatric unit. Telemedicine Journal and e-Health. 2011;17:603-608. [pmid: 21939381].
Grady B, Myers KM, Nelson EL, Belz N, Bennett L, Carnahan L, American Telemedicine Association Telemental Health Standards and Guidelines Working Group. Evidence-based practice for telemental health. Telemedicine Journal and e-Health. 2011;17:131-148. [pmid: 21385026].
Graf NM, Stebnicki MA. Using e-mail for clinical supervision in practicum: A qualitative analysis. Journal of Rehabilitation. 2002;68:41-49.
Graff CA, Hecker LL. E-therapy: Developing an ethical online practice. Hecker L, editor. Ethics and professional issues in couple and family therapy. 2010:243-255. New York. Routledge/Taylor & Francis Group.
Graham AL, Chang Y, Fang Y, Cobb NK, Tinkelman DS, Niaura RS, Mandelblatt JS. Cost-effectiveness of Internet and telephone treatment for smoking cessation: An economic evaluation of The iQUITT Study. Tobacco Control. 2012;22(6):e11. [pmid: 23010696].
Graham AL, Cobb NK, Papandonatos GD, Moreno JL, Kang H, Tinkelman DG, Abrams DB. A randomized trial of Internet and telephone treatment for smoking cessation. Archives of Internal Medicine. 2011;171:46-53. [pmid: 21220660].
Graham AL, Cobb NK, Raymond L, Sill S, Young J. Effectiveness of an Internet-based worksite smoking cessation intervention at 12 months. Journal of Occupational and Environmental Medicine. 2007;49:821-828. [pmid: 17693778].
Graham AL, Milner P, Saul JE, Pfaff L. Online advertising as a public health and recruitment tool: Comparison of different media campaigns to increase demand for smoking cessation interventions. Journal of Medical Internet Research. 2008;10:e50. [pmid: 19073542].
Graham C, Franses A, Kenwright M, Marks I. Psychotherapy by computer: A postal survey of responders to a teletext article. Psychiatric Bulletin. 2000;24:331-332.
Graham LA, Papandonatos DG. Reliability of Internet- versus telephone-administered questionnaires in a diverse sample of smokers. Journal of Medical Internet Research. 2008;10:e8. [pmid: 18364345].
Granholm E, Ben-Zeev D, Link PC, Bradshaw KR, Holden JL. Mobile Assessment and Treatment for Schizophrenia (MATS): A pilot trial of an interactive text-messaging intervention for medication adherence, socialization, and auditory hallucinations. Schizophrenia Bulletin. 2012;38:414-425. [pmid: 22080492].
Granholm E, Loh C, Swendsen J. Feasibility and validity of computerized ecological momentary assessment in schizophrenia. Schizophrenia Bulletin. 2008;34:507-514. [pmid: 17932087].
Graves AS. e-Learning update (two organizations using online training report). Behavioral Health Management. 2002;22:22-25.
Green BB, Cook AJ, Ralston JD, Fishman PA, Catz SL, Carlson J, Thompson RS. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: A randomized controlled trial. Journal of the American Medical Association. 2008;299:2857-2867. [pmid: 18577730].
Green KE, Iverson KM. Computerized cognitive–behavioral therapy in a stepped care model of treatment. Professional Psychology: Research and Practice. 2009;40:96-103.
Greene CJ, Morland LA, MacDonald A, Frueh BC, Grubbs KM, Rosen CS. How does tele-mental health affect group therapy process? Secondary analysis of a noninferiority trial. Journal of Consulting and Clinical Psychology. 2010;78:746-750. [pmid: 20873910].
Greidanus E, Everall RD. Helper therapy in an online suicide prevention community. British Journal of Guidance and Counselling. 2010;38:191-204.
Greist JH, Gustafson DH, Stauss FF, Rowse GL, Laughren TP, Chiles JA. Suicide risk prediction: A new approach. Suicide and Life-Threatening Behavior. 1974;4:212-223.
Greist JH, Marks IM, Baer L, Kobak KA, Wenzel KW, Hirsch MJ, Clary CM. Behavior therapy for obsessive–compulsive disorder guided by a computer or by a clinician compared with relaxation as a control. Journal of Clinical Psychiatry. 2002;63:138-145. [pmid: 11874215].
Griffiths KM, Christensen H. Quality of Web based information on treatment of depression: Cross sectional survey. British Medical Journal. 2000;321:1511-1515. [pmid: 11118181].
Griffiths KM, Christensen H. Review of randomised controlled trials of Internet interventions for mental disorders and related conditions. Clinical Psychologist. 2006;10:16-29.
Griffiths KM, Christensen H. Internet-based mental health programs: A powerful tool in the rural medical kit. Australian Journal of Rural Health. 2007;15:81-87. [pmid: 17441815].
Griffiths KM, Christensen H, Jorm AF, Evans K, Groves C. Effect of Web-based depression literacy and cognitive-behavioural therapy interventions on stigmatising attitudes to depression: Randomised controlled trial. British Journal of Psychiatry. 2004;185:342-349. [pmid: 15458995].
Griffiths KM, Farrer L, Christensen H. The efficacy of Internet interventions for depression and anxiety disorders: A review of randomised controlled trials. Medical Journal of Australia. 2010;192:S4-11. [pmid: 20528707].
Griffiths M. Online therapy: A cause for concern?. Psychologist. 2001;14:244-248.
Griffiths M. Online therapy for addictive behaviors. CyberPsychology and Behavior. 2005;8:555-561. [pmid: 16332166].
Griffiths M. Internet help and therapy for addictive behavior. Journal of CyberTherapy and Rehabilitation. 2009;2:43-52.
Griffiths M, Cooper G. Online therapy: Implications for problem gamblers and clinicians. British Journal of Guidance and Counselling. 2003;31:113-135.
Griffiths MD, Meredith A. Videogame addiction and its treatment. Journal of Contemporary Psychotherapy. 2009;39:247-253.
Griffiths MK, Calear LA, Banfield M. Systematic review on Internet support groups (ISGs) and depression (1): Do ISGs reduce depressive symptoms?. Journal of Medical Internet Research. 2009;11:e40. [pmid: 19793719].
Griffiths MK, Calear LA, Banfield M, Tam A. Systematic review on Internet support groups (ISGs) and depression (2): What is known about depression ISGs?. Journal of Medical Internet Research. 2009;11:e41. [pmid: 19793718].
Grohol JM. Future clinical directions: Professional development, pathology, and psychotherapy on-line. Gackenbach J, editor. Psychology and the Internet: Intrapersonal, interpersonal, and transpersonal implications. 1998:111-140. San Diego, CA. Academic Press.
Grohol JM. Online counseling: A historical perspective. Kraus R, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:51-68. New York. Elsevier Science.
Gros DF, Strachan M, Ruggiero KJ, Knapp RG, Frueh BC, Egede LE, Acierno R. Innovative service delivery for secondary prevention of PTSD in at-risk OIF-OEF service men and women. Contemporary Clinical Trials. 2011;32:122-128. [pmid: 20951235].
Gros DF, Veronee K, Strachan M, Ruggiero KJ, Acierno R. Managing suicidality in home-based telehealth. Journal of Telemedicine and Telecare. 2011;17:332-335. [pmid: 21844180].
Gros DF, Yoder M, Tuerk PW, Lozano BE, Acierno R. Exposure therapy for PTSD delivered to veterans via telehealth: Predictors of treatment completion and outcome and comparison to treatment delivered in person. Behavior Therapy. 2011;42:276-283. [pmid: 21496512].
Grover F Jr., Wu HD, Blanford C, Holcomb S, Tidler D. Computer-using patients want Internet services from family physicians. Journal of Family Practice. 2002;51:570-572. [pmid: 12100783].
Grover M, Naumann U, Mohammad-Dar L, Glennon D, Ringwood S, Eisler I, Schmidt U. A randomized controlled trial of an Internet-based cognitive-behavioural skills package for carers of people with anorexia nervosa. Psychological Medicine. 2011;41:2581-2591. [pmid: 21733215].
Grunwald M, Busse JC. Online consulting service for eating disorders—Analysis and perspectives. Computers in Human Behavior. 2003;19:469-477.
Grunwald M, Wesemann D. Special online consulting for patients with eating disorders and their relatives: Analysis of user characteristics and e-mail content. CyberPsychology and Behavior. 2007;10:57-63. [pmid: 17305449].
Gualtieri CT. An Internet-based symptom questionnaire that is reliable, valid, and available to psychiatrists, neurologists, and psychologists. Medscape General Medicine. 2007;9:3. [pmid: 18311353].
Guanipa C. Amigos: A bilingual Internet-based resource for school counselors. Professional School Counseling. 2001;4:362-365.
Guanipa C, Nolte LM, Lizarraga J. Using the Internet to help diverse populations: A bilingual Website. Journal of Technology in Human Services. 2002;19:13-23.
Gulec H, Moessner M, Mezei A, Kohls E, Tury F, Bauer S. Internet-based maintenance treatment for patients with eating disorders. Professional Psychology: Research and Practice. 2011;42:479-486.
Gun SY, Titov N, Andrews G. Acceptability of Internet treatment of anxiety and depression. Australasian Psychiatry. 2011;19:259-264. [pmid: 21682626].
Gunderson EW, Levin FR, Kleber HD, Fiellin DA, Sullivan LE. Evaluation of a combined online and in person training in the use of buprenorphine. Substance Abuse. 2006;27:39-45. [pmid: 17135179].
Gustafson DH, Boyle MG, Shaw BR, Isham A, McTavish F, Richards S, Johnson K. An e-health solution for people with alcohol problems. Alcohol Research and Health. 2011;33:327-337. [pmid: 23293549].
Gustafson DH, Brennan PF, Hawkins R. 2007. Investing in e-health: What it takes to sustain consumer health informatics. New York. Springer Publishing Co.
Gustafson DH, Greist JH, Stauss FF, Erdman H, Laughren T. A probabilistic system for identifying suicide attemptors. Computers and Biomedical Research. 1977;10:83-89. [pmid: 322942].
Gustafson DH, Hawkins R, Boberg E, Pingree S, Serlin RE, Graziano F, Chan CL. Impact of a patient-centered, computer-based health information/support system. American Journal of Preventive Medicine. 1999;16:1-9. [pmid: 9894548].
Gustafson DH, Hawkins R, McTavish F, Pingree S, Chen WC, Volrathongchai K, Serlin RC. Internet-based interactive support for cancer patients: Are integrated systems better?. Journal of Communication. 2008;58:238-257. [pmid: 21804645].
Gustafson DH, McTavish FM, Chih M-Y, Atwood AK, Johnson RA, Boyle MG, Shah D. A smartphone application to support recovery from alcoholism: A randomized clinical trial. JAMA Psychiatry. 2014;71(5):566-572. [pmid: 24671165].
Gustafson DH, McTavish FM, Schubert CJ, Johnson RA. The effect of a computer-based intervention on adult children of alcoholics. Journal of Addiction Medicine. 2012;6:24-28. [pmid: 22227576].
Gustafson DH, McTavish FM, Stengle W, Ballard D, Hawkins R, Shaw BR, Landucci G. Use and impact of eHealth system by low-income women with breast cancer. Journal of Health Communication. Suppl 1. 2005;10:195-218. [pmid: 16377608].
Gustafson DH, Shaw BR, Isham A, Baker T, Boyle MG, Levy M. Explicating an evidence-based, theoretically informed, mobile technology-based system to improve outcomes for people in recovery for alcohol dependence. Substance Use & Misuse. 2011;46:96-111. [pmid: 21190410].
Guterman JT, Kirk MA. Mental health counselors and the Internet. Journal of Mental Health Counseling. 1999;21:309-325.
Gutiérrez-Maldonado J, Ferrer-García M, Caqueo-Urizar A, Moreno E. Body image in eating disorders: the influence of exposure to virtual-reality environments. Cyberpsychology, Behavior, and Social Networking. 2010;13:521-531.
Haack MR, Burda-Cohee C, Alemi F, Harge A, Nemes S. Facilitating self-management of substance use disorders with online counseling: The intervention and study design. Journal of Addictions Nursing. 2005;16:41-46. [pmid: 22187519].
Haas A, Koestner B, Rosenberg J, Moore D, Garlow SJ, Sedway J, Nemeroff CB. An interactive Web-based method of outreach to college students at risk for suicide. Journal of American College Health. 2008;57:15-22. [pmid: 18682341].
Haas LJ, Benedict JG, Kobos JC. Psychotherapy by telephone: Risks and benefits for psychologists and consumers. Professional Psychology: Research and Practice. 1996;27:154-160.
Haberstroh S. College counselors' use of informal language online: Student perceptions of expertness, trustworthiness, and attractiveness. Cyberpsychology, Behavior, and Social Networking. 2010;13:455-459.
Haberstroh S, Duffey T, Evans M, Gee R, Trepal H. The experience of online counseling. Journal of Mental Health Counseling. 2007;29:269-282.
Haberstroh S, Parr G, Bradley L, Morgan-Fleming B, Gee R. Facilitating online counseling: Perspectives from counselors in training. Journal of Counseling and Development. 2008;86:460-470.
Haberstroh S, Parr G, Gee R, Trepal H. Interactive e-journaling in group work: Perspectives from counselor trainees. Journal for Specialists in Group Work. 2006;31:327-337.
Haberstroh S, Trepal H, Parr G. The confluence of technology and narrative approaches in group work—Techniques and suggestions for using interactive e-journals. Journal of Creativity in Mental Health. 2006;1:29-44.
Haemmerli K, Znoj H, Berger T. Internet-based support for infertile patients: A randomized controlled study. Journal of Behavioral Medicine. 2010;33:135-146. [pmid: 20039196].
Hague AL, White AA. Web-based intervention for changing attitudes of obesity among current and future teachers. Journal of Nutrition Education and Behavior. 2005;37:58-66. [pmid: 15882481].
Hailey D, Ohinmaa A, Roine R. Limitations in the routine use of telepsychiatry. Journal of Telemedicine and Telecare. 2009;15:28-31. [pmid: 19139217].
Hailey D, Roine R, Ohinmaa A. The effectiveness of telemental health applications: A review. Canadian Journal of Psychiatry/La Revue Canadienne de Psychiatrie. 2008;53:769-778.
Hale TM, Cotten SR, Drentea P, Goldner M. Rural–urban differences in general and health-related Internet use. American Behavioral Scientist. 2010;53:1304-1325.
Halkias D, Harkiolakis N, Thurman P, Caracatsanis S. Internet use for health-related purposes among Greek consumers. Telemedicine and e-Health. 2008;14:255-260. [pmid: 18570549].
Hall AS, Parsons J. Internet addiction: College student case study using best practices in cognitive behavior therapy. Journal of Mental Health Counseling. 2001;23:312-327.
Hall M, Hall P. 2009. Telemedicine reimbursement: A national scan of current policies and emerging initiatives. Sacramento, CA. California Telemedicine and eHealth Center.
Hall MJ, Tidwell WC. Internet recovery for substance abuse and alcoholism: An exploratory study of service users. Journal of Substance Abuse Treatment. 2003;24:161-167. [pmid: 12745033].
Hall P. Online psychosexual therapy: A summary of pilot study findings. Sexual and Relationship Therapy. 2004;19:167-178.
Hallett J, Maycock B, Kypri K, Howat P, McManus A. Development of a Web-based alcohol intervention for university students: Processes and challenges. Drug and Alcohol Review. 2009;28:31-39. [pmid: 19320673].
Hampton NZ, Houser R. Applications of computer-mediated communications via the Internet in rehabilitation counseling. Journal of Applied Rehabilitation Counseling. 2000;31:3-9.
Han DH, Renshaw PF, Sim ME, Kim JI, Arenella LS, Lyoo IK. The effect of Internet video game play on clinical and extrapyramidal symptoms in patients with schizophrenia. Schizophrenia Research. 2008;103:338-340. [pmid: 18304782].
Hanley T. Developing youth-friendly online counselling services in the United Kingdom: A small scale investigation into the views of practitioners. Counselling and Psychotherapy Research. 2006;6:182-185.
Hanley T. The working alliance in online therapy with young people: Preliminary findings. British Journal of Guidance and Counselling. 2009;37:257-269.
Hanley T, Reynolds DJ. Counselling psychology and the Internet: A review of the quantitative research into online outcomes and alliances within text-based therapy. Counselling Psychology Review. 2009;24:4-13.
Hardyman R, Hardy P, Brodie J, Stephens R. It's good to talk: Comparison of a telephone helpline and Website for cancer information. Patient Education and Counseling. 2005;57:315-320. [pmid: 15893214].
Harris M. Program: Empowering parents of children with special health care needs: Harnessing the power of the Internet. Health Education and Behavior. 2004;31:664-666.
Harris-Bowlsbey J. The Internet: Blessing or bane for the counseling profession?. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:39-49. Alexandria, VA. American Counseling Association.
Harvey-Berino J, Pintauro S, Buzzell P, DiGuilio M, Gold BC, Moldovan C, Ramirez E. Does using the Internet facilitate the maintenance of weight loss?. International Journal of Obesity. 2002;26:1254-1260. [pmid: 12187404].
Harvey-Berino J, Pintauro S, Buzzell P, Gold EC. Effect of Internet support on the long-term maintenance of weight loss. Obesity Research. 2004;12:320-329. [pmid: 14981225].
Harvey-Berino J, West D, Krukowski R, Prewitt E, VanBiervliet A, Ashikaga T, Skelly J. Internet delivered behavioral obesity treatment. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2010;51:123-128.
Hasin DS, Aharonovich E, Greenstein E. HealthCall for the smartphone: Technology enhancement of brief intervention in HIV alcohol dependent patients. Addiction Science & Clinical Practice. 2014;9:5. [pmid: 24533631].
Hasin DS, Aharonovich E, O'Leary A, Greenstein E, Pavlicova M, Arunajadai S, Johnston B. Reducing heavy drinking in HIV primary care: A randomized trial of brief intervention, with and without technological enhancement. Addiction. 2013;108(7):1230-1240. [pmid: 23432593].
Hassling L, Babic A, Lonn U, Casimir-Ahn H. A Web-based patient information system—Identification of patients' information needs. Journal of Medical Systems. 2003;27:247-257. [pmid: 12705457].
Hasson H, Brown C, Hasson D. Factors associated with high use of a workplace Web-based stress management program in a randomized controlled intervention study. Health Education Research. 2010;25:596-607. [pmid: 20150531].
Haug S, Meyer C, Gross B, Schorr G, Thyrian JR, Kordy H, John U. Continuous individual support of smoking cessation in socially deprived young adults via mobile phones—Results of a pilot study. Gesundheitswesen. 2008;70:364-371. [pmid: 18661460].
Haug S, Meyer C, John U. Efficacy of an Internet program for smoking cessation during and after inpatient rehabilitation treatment: A quasi-randomized controlled trial. Addictive Behaviors. 2011;36:1369-1372. [pmid: 21907496].
Haug S, Sedway J, Kordy H. Group processes and process evaluations in a new treatment setting: Inpatient group psychotherapy followed by Internet-chat aftercare groups. International Journal of Group Psychotherapy. 2008;58:35-53. [pmid: 18211213].
Haug S, Strauss B, Gallas C, Kordy H. New prospects for process research in group therapy: Text-based process variables in psychotherapeutic Internet chat groups. Psychotherapy Research. 2008;18:88-96. [pmid: 18815959].
Haveren RV, Habben CJ, Kuther TL. New psychologists online: Changing the face of psychology through technology. Morgan RD, Kuther TL, editors. Life after graduate school in psychology: Insider's advice from new psychologists. 2005:321-327. New York. Psychology Press.
Hawkins RP, Han JY, Pingree S, Shaw BR, Baker TB, Roberts LJ. Interactivity and presence of three eHealth interventions. Computers in Human Behavior. 2010;26:1081-1088. [pmid: 20617154].
Hayes BG. The use of multimedia instruction in counselor education: A creative teaching strategy. Journal of Creativity in Mental Health. 2008;3:243-253.
Hazen RA, Vasey MW, Schmidt NB. Attentional retraining: A randomized clinical trial for pathological worry. Journal of Psychiatric Research. 2009;43:627-633. [pmid: 18722627].
Hedman E, Andersson E, Ljotsson B, Andersson G, Ruck C, Lindefors N. Cost-effectiveness of Internet-based cognitive behavior therapy vs. cognitive behavioral group therapy for social anxiety disorder: Results from a randomized controlled trial. Behaviour Research and Therapy. 2011;49:729-736. [pmid: 21851929].
Heeren A, Lievens L, Philippot P. How does attention training work in social phobia: disengagement from threat or re-engagement to non-threat?. Journal of Anxiety Disorders. 2011;25:1108-1115. [pmid: 21907539].
Heidgerken AD, Lewin AB, Geffken GR, Gelfand KM, Storch EA, Malasanos T. Online diabetes education: Design and evaluation with prospective diabetes camp counsellors. Journal Telemedicine and Telecare. 2005;11:93-96.
Heinicke BE, Paxton SJ, McLean SA, Wertheim EH. Internet-delivered targeted group intervention for body dissatisfaction and disordered eating in adolescent girls: A randomized controlled trial. Journal of Abnormal Child Psychology. 2007;35:379-391. [pmid: 17243014].
Heinlen KT, Welfel ER, Richmond EN, O'Donnell MS. The nature, scope, and ethics of psychologists' e-therapy Web sites: What consumers find when surfing the Web. Psychotherapy: Theory, Research, Practice, Training. 2003;40:112-124.
Heinlen KT, Welfel ER, Richmond EN, Rak CF. The scope of Webcounseling: A survey of services and compliance with NBCC standards for the ethical practice of Webcounseling. Journal of Counseling and Development. 2003;81:61-69.
Helgadottir FD, Menzies RG, Onslow M, Packman A, O'Brian S. Online CBT I: Bridging the gap between Eliza and modern online CBT treatment packages. Behaviour Change. 2009;26:245-253.
Helgadottir FD, Menzies RG, Onslow M, Packman A, O'Brian S. Online CBT II A phase I trial of a standalone, online CBT treatment program for social anxiety in stuttering. Behaviour Change. 2009;26:254-270.
Helm S, Koyanagi C, Else I, Horton M, Fukuda M. Public–academic partnerships: The University of Hawai'i Rural Health Collaboration: Partnerships to provide adult telepsychiatry services. Psychiatric Services. 2010;61:961-963. [pmid: 20889630].
Helwig AL, Lovelle A, Guse CE, Gottlieb MS. An office-based Internet patient education system: A pilot study. The Journal of Family Practice. 1999;48:123-127. [pmid: 10037543].
Helzer JE, Badger GJ, Rose GL, Mongeon JA, Searles JS. Decline in alcohol consumption during two years of daily reporting. Journal of Studies on Alcohol. 2002;63:551-558. [pmid: 12380851].
Hemelrijk E, van Ballegooijen W, Donker T, van Straten A, Kerkhof A. Internet-based screening for suicidal ideation in common mental disorders. Crisis. 2012;33:215-221. [pmid: 22713975].
Herbst N, Voderholzer U, Stelzer N, Knaevelsrud C, Hertenstein E, Schlegl S, Külz AK. The potential of telemental health applications for obsessive–compulsive disorder. Clinical Psychology Review. 2012;32:454-466. [pmid: 22705583].
Heron KE, Smyth JM. Ecological momentary interventions: Incorporating mobile technology into psychosocial and health behaviour treatments. British Journal of Health Psychology. 2010;15:1-39. [pmid: 19646331].
Hertlein KM, Piercy FP. Therapists' assessment and treatment of Internet infidelity cases. Journal of Marital and Family Therapy. 2008;34:481-497. [pmid: 19017187].
Hester RK, Delaney HD. Behavioral self-control program for Windows: Results of a controlled clinical trial. Journal of Consulting and Clinical Psychology. 1997;65:686-693. [pmid: 9256570].
Hester RK, Delaney HD, Campbell W. Moderatedrinking.com and moderation management: Outcomes of a randomized clinical trial with non-dependent problem drinkers. Journal of Consulting and Clinical Psychology. 2011;79:215-224. [pmid: 21319896].
Hester RK, Delaney HD, Campbell W. The College Drinker's Check-Up: Outcomes of two randomized clinical trials of a computer-delivered intervention. Psychology of Addictive Behaviors. 2012;26:1-12. [pmid: 21823769].
Hester RK, Delaney HD, Campbell W, Handmaker N. A Web application for moderation training: Initial results of a randomized clinical trial. Journal of Substance Abuse Treatment. 2009;37:266-276. [pmid: 19339137].
Hester RK, Miller JH. 2010. Computer-based tools for diagnosis and treatment of alcohol problems. Bethesda, MD. National Institute on Alcohol Abuse and Alcoholism.
Hester RK, Squires DD, Delaney HD. The Drinker's Check-Up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. Journal of Substance Abuse Treatment. 2005;28:159-169. [pmid: 15780546].
Hickie IB, Davenport TA, Luscombe GM, Moore M, Griffiths KM, Christensen H. Practitioner-supported delivery of Internet-based cognitive behaviour therapy: Evaluation of the feasibility of conducting a cluster randomised trial. Medical Journal of Australia. 2010;192:S31-S35. [pmid: 20528705].
Hicks CL, von Baeyer CL, McGrath PJ. Online psychological treatment for pediatric recurrent pain: A randomized evaluation. Journal of Pediatric Psychology. 2006;31:724-736. [pmid: 16093516].
Hile MG, Adkins RE. Do substance abuse and mental health clients prefer automated assessments?. Behavior Research Methods, Instruments & Computers. 1997;29:146-150.
Hill RD, Luptak MK, Rupper RW, Bair B, Peterson C, Dailey N, Hicken BL. Review of Veterans Health Administration telemedicine interventions. American Journal of Managed Care. 2010;16:e302-e310. [pmid: 21322300].
Hill W, Weinert C, Cudney S. Influence of a computer intervention on the psychological status of chronically ill rural women: Preliminary results. Nursing Research. 2006;55:34-42. [pmid: 16439927].
Hilty DM, Nesbitt TS, Marks SL, Callahan EJ. Effects of telepsychiatry on the doctor–patient relationship: Communication, satisfaction and relevant issues. Primary Psychiatry. 2002;9:29-34.
Hilvert-Bruce Z, Rossouw PJ, Wong N, Sunderland M, Andrews G. Adherence as a determinant of effectiveness of Internet cognitive behavioural therapy for anxiety and depressive disorders. Behaviour Research and Therapy. 2012;50:463-468. [pmid: 22659155].
Himle JA, Fischer DJ, Muroff JR, Van Etten ML, Lokers LM, Abelson JL, Hanna GL. Videoconferencing-based cognitive–behavioral therapy for obsessive–compulsive disorder. Behaviour Research and Therapy. 2006;44:1821-1829. [pmid: 16466688].
Hirai M, Clum GA. An Internet-based self-change program for traumatic event related fear, distress, and maladaptive coping. Journal of Traumatic Stress. 2005;18:631-636. [pmid: 16382433].
Hirai M, Clum GA. A meta-analytic study of self-help interventions for anxiety problems. Behavior Therapy. 2006;37:99-111. [pmid: 16942965].
Hobbs LJ, Yan Z. Cracking the walnut: Using a computer game to impact cognition, emotion, and behavior of highly aggressive fifth grade students. Computers in Human Behavior. 2008;24:421-438.
Hoffmann WA. Telematic technologies in mental health caring: A Web-based psychoeducational program for adolescent suicide survivors. Issues in Mental Health Nursing. 2006;27:461-474. [pmid: 16613799].
Hoge MA, Morris JA, Daniels AS, Stuart GW, Huey LY, Adams N. 2007. An action plan for behavioral health workforce development: A framework for discussion. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Holden G, Rosenberg G, Meenaghan TM. Information for social work practice: Observations regarding the role of the World Wide Web. Social Work in Health Care. 2000;32:1-8. [pmid: 11291889].
Holländare F, Johnsson S, Randestad M, Tillfors M, Carlbring P, Andersson G, Engström I. Randomized trial of Internet-based relapse prevention for partially remitted depression. Acta Psychiatrica Scandinavica. 2011;124:285-294. [pmid: 21401534].
Holmes C, Foster V. A preliminary comparison study of online and face-to-face counseling: Client perceptions of three factors. Journal of Technology in Human Services. 2012;30:14-31.
Holmes EA, Mathews A, Dalgleish T, Mackintosh B. Positive interpretation training: Effects of mental imagery versus verbal training on positive mood. Behavior Therapy. 2006;37:237-247. [pmid: 16942975].
Holtyn AF, Koffamus MN, DeFulio A, Sigurdsson SO, Strain EC, Schwartz RP, Silverman K. The therapeutic workplace to promote treatment engagement and drug abstinence in out-of-treatment injection drug users: A randomized controlled trial. Preventive Medicine. 2014;68:62-70. [pmid: 24607365].
Hong T. The Internet and tobacco cessation: The roles of Internet self-efficacy and search task on the information-seeking process. Journal of Computer-Mediated Communication. 2006;11:536-556.
Hopps SL, Pepin M, Boisvert JM. The effectiveness of cognitive–behavioral group therapy for loneliness via inter-relay-chat among people with physical disabilities. Psychotherapy: Theory, Research, Practice, Training. 2003;40:136-147.
Horgan A, Sweeney J. Young students' use of the Internet for mental health information and support. Journal of Psychiatric and Mental Health Nursing. 2010;17:117-123. [pmid: 20465756].
Horgan CM, Merrick EL, Reif S, Stewart M. Datapoints: Internet-based behavioral health services in health plans. Psychiatric Services. 2007;58:307. [pmid: 17325101].
Horgan CM, Merrick EL, Reif S, Stewart M. Internet-based behavioral health services in health plans. Psychiatric Services. 2007;58:307. [pmid: 17325101].
Horrigan J. 2009. Wireless Internet use. Washington, DC. Pew Research Center.
Hotta K, Kinumi K, Naito K, Kuroki K, Sakane H, Imai A, Tobe K. An intensive group therapy programme for smoking cessation using nicotine patch and Internet mailing supports in a university setting. International Journal of Clinical Practice. 2007;61:1997-2001. [pmid: 17997805].
Houston TK, Cooper LA, Ford DE. Internet support groups for depression: A 1-year prospective cohort study. American Journal of Psychiatry. 2002;159:2062-2068. [pmid: 12450957].
Houston TK, Cooper LA, Vu HT, Kahn J, Toser J, Ford DE. Screening the public for depression through the Internet. Psychiatric Services. 2001;52:362-367. [pmid: 11239106].
Houston TK, Ford DE. A tailored Internet-delivered intervention for smoking cessation designed to encourage social support and treatment seeking: Usability testing and user tracing. Informatics for Health & Social Care. 2008;33:5-19. [pmid: 18604759].
Hsiung RC. Suggested principles of professional ethics for the online provision of mental health services. Telemedicine Journal and e-Health. 2001;7:39-45. [pmid: 11321708].
Huang MP, Alessi NE. The Internet and the future of psychiatry. American Journal of Psychiatry. 1996;153:861-869. [pmid: 8659607].
Hubbard RL, Leimberger JD, Haynes L, Patkar AA, Holter J, Liepman MR, National Institute on Drug Abuse. Telephone enhancement of long-term engagement (TELE) in continuing care for substance abuse treatment: A NIDA clinical trials network (CTN) study. American Journal of Addiction. 2007;16:495-502.
Hufford BJ, Glueckauf RL, Webb PM. Home-based, interactive videoconferencing for adolescents with epilepsy and their families. Rehabilitation Psychology. 1999;44:176-193.
Hughes B, Joshi I, Wareham J. Health 2.0 and medicine 2.0: Tensions and controversies in the field. Journal of Medical Internet Research. 2008;10:e23. [pmid: 18682374].
Hughes G, Hudgins B, Hooper JE, Wallace B. User satisfaction with rehabilitation services delivered using Internet video. Journal of Telemedicine and Telecare. 2003;9:180-183. [pmid: 12877782].
Humphreys K, Klaw E. Can targeting nondependent problem drinkers and providing Internet-based services expand access to assistance for alcohol problems? A study of the moderation management self-help/mutual aid organization. Journal of Studies on Alcohol. 2001;62:528-532. [pmid: 11513231].
Hunkeler EM, Hargreaves WA, Fireman B, Terdiman J, Meresman JF, Porterfield Y, Taylor CB. A Web-delivered care management and patient self-management program for recurrent depression: A randomized trial. Psychiatric Services. 2012;63(11):1063-1071. [pmid: 22983558].
Hunt MG, Moshier S, Milonova M. Brief cognitive-behavioral Internet therapy for irritable bowel syndrome. Behaviour Research and Therapy. 2009;47:797-802. [pmid: 19570525].
Hunter CM, Peterson AL, Alvarez LM, Poston WC, Brundige AR, Haddock CK, Foreyt JP. Weight management using the Internet: A randomized controlled trial. American Journal of Preventive Medicine. 2008;34(2):119-126. [pmid: 18201641].
Huppert JD, Kivity Y, Barlow DH, Gorman JM, Shear MK, Woods SW. Therapist effects and outcomes—Alliance correlation in cognitive behavior therapy for panic disorder with agoraphobia. Behaviour Research and Therapy. 2014;52:26-34. [pmid: 24275067].
Hustad JTP, Barnett NP, Borsari B, Jackson KM. Web-based alcohol prevention for incoming college students: A randomized controlled trial. Addictive Behaviors. 2010;35:183-189. [pmid: 19900763].
Hyler SE, Gangure DP. A review of the costs of telepsychiatry. Psychiatric Services. 2003;54:976-980. [pmid: 12851433].
Hyler SE, Gangure DP, Batchelder ST. Can telepsychiatry replace in-person psychiatric assessments? A review and meta-analysis of comparison studies. CNS Spectrums. 2005;10:403-413. [pmid: 15858458].
Ilic D. The role of the Internet on patient knowledge management, education, and decision-making. Telemedicine and e-Health. 2010;16:664-669. [pmid: 20575610].
Institute of Medicine. 2006. Improving the quality of health care for mental and substance-use conditions: Quality chasm series. Washington, DC. Author.
International Society for Mental Health Online. 2010. Assessing a person's suitability for online therapy. Marietta, GA. Author.
International Telecommunication Union. 2011. The world in 2011: ITC facts and figures. Geneva. Author.
International Telecommunication Union. 2012. Key global telecom indicators for the world telecommunication service sector. Geneva. Author.
International Telecommunication Union. 2015. ICT facts and figures. Geneva. Author.
Irvine AB, Bourgeois M, Billow M, Seeley JR. Internet training for nurse aides to prevent resident aggression. Journal of the American Medical Directors Association. 2007;8:519-526. [pmid: 17931576].
Ishizuki T, James Cotter J. Social workers' use of the Internet and e-mail to help clients in Virginia. Journal of Technology in Human Services. 2009;27:127-140.
Iverson GL, Brooks BL, Young AH. Identifying neurocognitive impairment in depression using computerized testing. Applied Neuropsychology. 2009;16:254-261. [pmid: 20183180].
Iverson SA, Howard KB, Penney BK. Impact of Internet use on health-related behaviors and the patient-physician relationship: A survey-based study and review. Journal of the American Osteopathic Association. 2008;108:699-711. [pmid: 19075034].
Jacobi C, Morris L, Beckers C, Bronisch-Holtze J, Winter J, Winzelberg AJ, Taylor CB. Maintenance of Internet-based prevention: A randomized controlled trial. International Journal of Eating Disorders. 2007;40:114-119. [pmid: 17080447].
Jadad AA. What will it take to bring the Internet into the consulting room? We cannot remain oblivious to our patients' expectations. Journal of General Internal Medicine. 2005;20:787-788. [pmid: 16050894].
Jameson JP, Farmer MS, Head KJ, Fortney J, Teal CR. VA community mental health service providers' utilization of and attitudes toward telemental health care: The gatekeeper's perspective. Journal of Rural Health. 2011;27:425-432. [pmid: 21967387].
Jansen W, Scarfone K. 2008. Guidelines on cell phone and PDA security: Recommendations of the National Institute of Standards and Technology. Washington, DC. U.S. Government Printing Office.
Japuntich SJ, Zehner ME, Smith SS, Jorenby DE, Valdez JA, Fiore MC, Gustafson DH. Smoking cessation via the Internet: A randomized clinical trial of an Internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine and Tobacco Research. 2006;8(Suppl 1):S59-S67. [pmid: 17491172].
Jencius M, Paez S. Converting counselor luddites: Winning over technology-resistant counselors. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: An encore. 2005:81-114. Austin, TX. Pro-Ed.
Jencius M, Sager DE. The practice of marriage and family counseling in cyberspace. Family Journal. 2001;9:295-301.
Jerome LW, Zaylor C. Cyberspace: Creating a therapeutic environment for telehealth applications. Professional Psychology: Research and Practice. 2000;31:478-483.
Jerry P, Collins S. Web-based education in the human services: Use of Web-based video clips in counselling skills training. Journal of Technology in Human Services. 2005;23:183-199.
Jeyaraj A, Rottman JW, Lacity MC. A review of the predictors, linkages, and biases in IT innovation adoption research. Journal of Information Technology. 2006;21:1-23.
Jin SAA. The roles of regulatory focus and medical recommendation avatars' trustworthiness in virtual environment-based e-health. Cyberpsychology, Behavior, and Social Networking. 2010;13:461-466.
Johansen AB, Lumley M, Cano A. Effects of video-based therapy preparation targeting experiential acceptance or the therapeutic alliance. Psychotherapy. 2011;48:163-169. [pmid: 21639659].
Johansson L, Carlbring P, Ghaderi A, Andersson G. Emotional Stroop via Internet among individuals with eating disorders. Scandinavian Journal of Psychology. 2008;49:69-76. [pmid: 18190404].
Johnson GL, Ramaprasad A. Patient–physician relationships in the information age. Marketing Health Services. 2000;20:20-27. [pmid: 11923940].
Johnston O, Startup H, Lavender A, Godfrey E, Schmidt U. Therapeutic writing as an intervention for symptoms of bulimia nervosa: Effects and mechanism of change. International Journal of Eating Disorders. 2010;43:405-419. [pmid: 19544556].
Joiner T, Kalafat J, Draper J, Stokes H, Knudson M, Berman AL, McKeon R. Establishing standards for the assessment of suicide risk among callers to the National Suicide Prevention Lifeline. Suicide and Life-Threatening Behavior. 2007;37:353-365. [pmid: 17579546].
Joinson A. Causes and implications of disinhibited behavior on the Internet. Gackenbach J, editor. Psychology and the Internet: Intrapersonal, interpersonal, and transpersonal implications. 1998:43-60. San Diego, CA. Academic Press.
Joinson AN, Paine CB. Self-disclosure, privacy and the Internet. Joinson A, McKenna K, Postmes T, Reips UD, editors. The Oxford handbook of Internet psychology. 2007:237-252. Oxford, United Kingdom. Oxford University Press.
Jonasson J, Linne Y, Neovius M, Rossner S. An Internet-based weight loss programme—A feasibility study with preliminary results from 4209 completers. Scandinavian Journal of Public Health. 2009;37:75-82. [pmid: 18684784].
Jones BN III, Colenda CC. Telemedicine and geriatric psychiatry. Psychiatric Services. 1997;48:783-785. [pmid: 9175185].
Jones EG, Goldsmith M, Effken J, Button K, Crago M. Creating and testing a Deaf-friendly, stop-smoking Web site intervention. American Annals of the Deaf. 2010;155:96-102. [pmid: 20503910].
Jones G, Stokes A. 2009. Online counselling: A handbook for practitioners. Basingstoke, England. Palgrave Macmillan.
Jones JB, Snyder CF, Wu AW. Issues in the design of Internet-based systems for collecting patient-reported outcomes. Quality of Life Research. 2007;16:1407-1417. [pmid: 17668293].
Jones M, Luce KH, Osborne MI, Taylor K, Cunning D, Doyle AC, Taylor CB. Randomized, controlled trial of an Internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics. 2008;121:453-462. [pmid: 18310192].
Jones P. Research into therapists perceptions of therapeutic change using vignettes and MSN messenger. European Journal of Psychotherapy and Counselling. 2009;11:251-266.
Jones R. Identity commitments in personal stories of mental illness on the Internet. Narrative Inquiry. 2005;15:293-322.
Jones RM, Leonard S, Birmingham L. Setting up a telepsychiatry service. Psychiatric Bulletin. 2006;30:464-467.
Jones S, Fox S. 2009. The social life of health information: Americans' pursuit of health takes place within a widening network of both online and offline sources. Washington, DC. Pew Research Center.
Jones WP. Testing and counseling: A marriage saved by the Internet?. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: An encore. 2005:183-202. Austin, TX. Pro-Ed.
Joo NS, Kim BT. Mobile phone short message service messaging for behaviour modification in a community-based weight control programme in Korea. Journal of Telemedicine and Telecare. 2007;13:416-420. [pmid: 18078554].
Jordan CJ. Evolution of autism support and understanding via the World Wide Web. Intellectual and Developmental Disabilities. 2010;48:220-227. [pmid: 20597733].
Jordan ET, Ray EM, Johnson P, Evans WD. Text4Baby: Using text messaging to improve maternal and newborn health. Nursing for Women's Health. 2011;15:206-212.
Joshi A, Arora M, Dai L, Price K, Vizer L, Sears A. Usability of a patient education and motivation tool using heuristic evaluation. Journal of Medical Internet Research. 2009;11:e47. [pmid: 19897458].
Josman N, Somer E, Reisberg A, Weiss PL, Garcia-Palacios A, Hoffman H. BusWorld: Designing a virtual environment for post-traumatic stress disorder in Israel: A protocol. Cyberpsychology & Behavior. 2006;9:241-244. [pmid: 16640487].
Jucks R, Bromme R. Choice of words in doctor–patient communication: An analysis of health-related Internet sites. Health Communication. 2007;21:267-277. [pmid: 17567258].
Julian K, Beard C, Schmidt NB, Powers MB, Smits JA. Attention training to reduce attention bias and social stressor reactivity: An attempt to replicate and extend previous findings. Behaviour Research and Therapy. 2012;50:350-358. [pmid: 22466022].
Juzang I, Fortune T, Black S, Wright E, Bull S. A pilot programme using mobile phones for HIV prevention. Journal of Telemedicine and Telecare. 2011;17:150-153. [pmid: 21270049].
Kahan M. Integration of psychodynamic and cognitive-behavioral therapy in a virtual environment. CyberPsychology & Behavior. 2000;3:179-183.
Kalafat J, Gould MS, Harris Munfakh JL, Kleinman M. An evaluation of crisis hotline outcomes: Part 1: Non-suicidal crisis callers. Suicide and Life-Threatening Behavior. 2007;37:322-337. [pmid: 17579544].
Kaldo V, Levin S, Widarsson J, Buhrman M, Larsen HC, Andersson G. Internet versus group cognitive-behavioral treatment of distress associated with tinnitus: A randomized controlled trial. Behavior Therapy. 2008;39:348-359. [pmid: 19027431].
Kaldo-Sandstrom V, Larsen HC, Andersson G. Internet-based cognitive–behavioral self-help treatment of tinnitus: Clinical effectiveness and predictors of outcome. American Journal of Audiology. 2004;13:185-192. [pmid: 15903144].
Kalman TP. FRONTLINE—Clinical encounters with Internet pornography. Journal of the American Academy of Psychoanalysis and Dynamic Psychiatry. 2008;36:593-618. [pmid: 19113956].
Kaltenthaler E, Brazier J, De NE, Tumur I, Ferriter M, Beverley C, Sutcliff P. Computerised cognitive behaviour therapy for depression and anxiety update: A systematic review and economic evaluation. Health Technology Assessment. xi. 2006;10:iii-iii. 168. [pmid: 16959169].
Kaltenthaler E, Parry G, Beverley C, Ferriter M. Computerised cognitive–behavioural therapy for depression: Systematic review. British Journal of Psychiatry. 2008;193:181-184. [pmid: 18757972].
Kaltenthaler E, Sutcliffe P, Parry G, Beverley C, Rees A, Ferriter M. The acceptability to patients of computerized cognitive behaviour therapy for depression: A systematic review. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2008;38:1521-1530.
Kaminer Y, Burleson JA, Burke RH. Efficacy of outpatient aftercare for adolescents with alcohol use disorders: A randomized controlled study. Journal of the American Academy of Child & Adolescent Psychiatry. 2008;47:1405-1412. [pmid: 18978635].
Kaminer Y, Burleson JA, Goldston DB, Burke RH. Suicidal ideation among adolescents with alcohol use disorders during treatment and aftercare. American Journal on Addictions. 2006;15:43-49. [pmid: 17182419].
Kaminer Y, Litt MD, Burke RH, Burleson JA. An interactive voice response (IVR) system for adolescents with alcohol use disorders: A pilot study. American Journal on Addictions. 2006;15:122-125. [pmid: 17182427].
Kaminer Y, Napolitano C. Dial for therapy: Aftercare for adolescent substance use disorders. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:1171-1174. [pmid: 15322422].
Kanani K, Regehr C. Clinical, ethical, and legal issues in e-therapy. Families in Society. 2003;84:155-162.
Kang SH, Gratch J. People like virtual counselors that highly disclose about themselves. Studies in Health Technology and Informatics. 2011;167:143-148. [pmid: 21685657].
Kanz JE. Clinical-supervision.com: Issues in the provision of online supervision. Professional Psychology: Research and Practice. 2001;32:415-420.
Kaplan K, Salzer MS, Solomon P, Brusilovskiy E, Cousounis P. Internet peer support for individuals with psychiatric disabilities: A randomized controlled trial. Social Science and Medicine. 2011;72:54-62. [pmid: 21112682].
Karlin B. A brave new world of treatment (eGetgoing—Online treatment). Behavioral Health Management. 2001;21:39-41.
Karno M, Farabee D, Brecht ML, Rawson R. Patient reactance moderates the effect of directive telephone counseling for methamphetamine users. Journal of Studies on Alcohol. 2012;73:844-850.
Kaufman N. Internet and information technology use in treatment of diabetes. International Journal of Clinical Practice. 2010;64(Suppl. s166):41-46. [pmid: 20377663].
Kawabata A, Tamura T. Online religion in Japan: Websites and religious counseling from a comparative cross-cultural perspective. Journal of Computer-Mediated Communication. 2007;12:999-1019.
Kay-Lambkin FJ, Baker AL, Kelly BJ, Lewin TJ. It's worth a try: The treatment experiences of rural and urban participants in a randomized controlled trial of computerized psychological treatment for comorbid depression and alcohol/other drug use. Journal of Dual Diagnosis. 2012;8:262-276.
Kay-Lambkin FJ, Baker AL, Lewin TJ, Carr VJ. Computer-based psychological treatment for comorbid depression and problematic alcohol and/or cannabis use: A randomized controlled trial of clinical efficacy. Addiction. 2009;104:378-388. [pmid: 19207345].
Kedar I, Ternullo JL, Weinrib CE, Kelleher KM, Brandling-Bennett H, Kvedar JC. Internet based consultations to transfer knowledge for patients requiring specialised care: Retrospective case review. BMJ: British Medical Journal. 2003;326:696-699. [pmid: 12663408].
Keller PA, Bailey LA, Koss KJ, Baker TB, Fiore MC. Organization, financing, promotion, and cost of U.S. quitlines, 2004. American Journal of Preventive Medicine. 2007;32:32-37. [pmid: 17184958].
Kenardy J, McCafferty K, Rosa V. Internet-delivered indicated prevention for anxiety disorders: A randomized controlled trial. Behavioural and Cognitive Psychotherapy. 2003;31:279-289.
Kenardy J, McCafferty K, Rosa V. Internet-delivered indicated prevention for anxiety disorders: Six-month follow-up. Clinical Psychologist. 2006;10:39-42.
Kenwright M, Marks IM. Computer-aided self-help for phobia/panic via Internet at home: A pilot study. British Journal of Psychiatry. 2004;184:448-449. [pmid: 15123511].
Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive–compulsive disorder: Randomized controlled trial. Journal of Clinical Psychology. 2005;61:1499-1508. [pmid: 16173084].
Kernsmith PD, Kernsmith RM. A safe place for predators: Online treatment of recovering sex offenders. Journal of Technology in Human Services. 2008;26:223-238.
Kerr C, Murray E, Burns J, Turner I, Westwood MA, MacAdam C, Patterson D. Applying user-generated quality criteria to develop an Internet intervention for patients with heart disease. Journal of Telemedicine and Telecare. 2008;14:124-127. [pmid: 18430276].
Keski-Rahkonen A, Tozzi F. The process of recovery in eating disorder sufferers' own words: An Internet-based study. International Journal of Eating Disorders. 2005;37:S80-S86. [pmid: 15852327].
Kessler D, Lewis G, Kaur S, Wiles N, King M, Weich S, Peters T. Therapist-delivered Internet psychotherapy for depression in primary care: A randomised controlled trial. The Lancet. 2009;374:628-634.
Khalil I, Sufi F. Cooperative remote video consultation on demand for e-patients. Journal of Medical Systems. 2009;33:475-483. [pmid: 20052899].
Kiluk BD, Nich C, Babuscio T, Carroll KM. Quality versus quantity: Acquisition of coping skills following computerized cognitive behavioral therapy for substance use disorders. Addiction. 2010;105:2120-2127. [pmid: 20854334].
Kiluk BD, Sugarman DE, Nich C, Gibbons CJ, Martino S, Rounsaville BJ, Carroll KM. A methodological analysis of randomized clinical trials of computer-assisted therapies for psychiatric disorders: Toward improved standards for an emerging field. American Journal of Psychiatry. 2011;168:790-799. [pmid: 21536689].
Kim JU. A reality therapy group counseling program as an Internet addiction recovery method for college students in Korea. International Journal of Reality Therapy. 2007;26:3-9.
Kim K, Kim SI, Cha KR, Park J, Rosenthal MZ, Kim JJ, Kim CH. Development of a computer-based behavioral assessment of checking behavior in obsessive-compulsive disorder. Comprehensive Psychiatry. 2001;51:86-93. [pmid: 19932831].
Kim SI, Kim HS. Effectiveness of mobile and Internet intervention in patients with obese type 2 diabetes. International Journal of Medical Informatics. 2008;77:399-404. [pmid: 17881285].
King R, Bambling M, Lloyd C, Gomurra R, Smith S, Reid W, Wegner K. Online counselling: The motives and experiences of young people who choose the Internet instead of face to face or telephone counselling. Counselling and Psychotherapy Research. 2006;6:169-174.
King R, Bambling M, Reid W, Thomas I. Telephone and online counselling for young people: A naturalistic comparison of session outcome, session impact and therapeutic alliance. Counselling and Psychotherapy Research. 2006;6:175-181.
King SA, Engi S, Poulos ST. Using the Internet to assist family therapy. British Journal of Guidance and Counselling. 1998;26:43-52.
King SA, Moreggi D. Internet therapy and self-help groups—The pros and cons. Gackenbach J, editor. Psychology and the Internet: Intrapersonal, interpersonal, and transpersonal implications. 1998:77-109. San Diego, CA. Academic Press.
King SA, Poulos ST. Using the Internet to treat generalized social phobia and avoidant personality disorder. CyberPsychology and Behavior. 1998;1:29-36.
King TK, Borrelli B, Black C, Pinto BM, Marcus BH. Minority women and tobacco: Implications for smoking cessation interventions. Annals of Behavioral Medicine. 1997;19:301-313. [pmid: 9603705].
King VL, Stoller KB, Kidorf M, Kindbom K, Hursh S, Brady T, Brooner RK. Assessing the effectiveness of an Internet-based videoconferencing platform for delivering intensified substance abuse counseling. Journal of Substance Abuse Treatment. 2009;36:331-338. [pmid: 18775625].
Kirkby KC, Berrios GE, Daniels BA, Menzies RG, Clark A, Romano A. Process–outcome analysis in computer-aided treatment of obsessive–compulsive disorder. Comprehensive Psychiatry. 2000;41:259-265. [pmid: 10929793].
Kirkby KC, Matthews A, Scanlan J. Internet delivered images for exposure in specific phobia, design considerations for self-directed therapy. Annual Review of CyberTherapy and Telemedicine. 2010;8:58-60.
Kiropoulos LA, Klein B, Austin DW, Gilson K, Pier C, Mitchell J, Ciechomski L. Is Internet-based CBT for panic disorder and agoraphobia as effective as face-to-face CBT?. Journal of Anxiety Disorders. 2008;22:1273-1284. [pmid: 18289829].
Kisely S, Ong G, Takyar A. A survey of the quality of Web based information on the treatment of schizophrenia and attention deficit hyperactivity disorder. Australian and New Zealand Journal of Psychiatry. 2003;37:85-91. [pmid: 12534662].
Kivits J. Informed patients and the Internet: A mediated context for consultations with health professionals. Journal of Health Psychology. 2006;11:269-282. [pmid: 16464924].
Klein B, Austin D, Pier C, Kiropoulos L, Shandley K, Mitchell J, Ciechomski L. Internet-based treatment for panic disorder: Does frequency of therapist contact make a difference?. Cognitive Behaviour Therapy. 2009;38:100-113. [pmid: 19306149].
Klein B, Meyer D, Austin DW, Kyrios M. Anxiety online: A virtual clinic: Preliminary outcomes following completion of five fully automated treatment programs for anxiety disorders and symptoms. Journal of Medical Internet Research. 2011;13:e89. [pmid: 22057287].
Klein B, Mitchell J, Abbott J, Shandley K, Austin D, Gilson K, Redman T. A therapist-assisted cognitive behavior therapy Internet intervention for posttraumatic stress disorder: Pre-, post- and 3-month follow-up results from an open trial. Journal of Anxiety Disorders. 2010;24:635-644. [pmid: 20447802].
Klein B, Mitchell J, Gilson K, Shandley K, Austin D, Kiropoulos L, Cannard G. A therapist-assisted Internet-based CBT intervention for posttraumatic stress disorder: Preliminary results. Cognitive Behaviour Therapy. 2009;38:121-131. [pmid: 20183691].
Klein B, Richards JC. A brief Internet-based treatment for panic disorder. Behavioural and Cognitive Psychotherapy. 2001;29:113-117.
Klein B, Richards JC, Austin DW. Efficacy of Internet therapy for panic disorder. Journal of Behavior Therapy and Experimental Psychiatry. 2006;37:213-238. [pmid: 16126161].
Klemm P, Wheeler E. Cancer caregivers online: Hope, emotional roller coaster, and physical/emotional/psychological responses. CIN: Computers, Informatics, Nursing. 2005;23:38-45.
Klinger E, Legeron P, Roy S, Chemin I, Lauer F, Nugues P. Virtual reality exposure in the treatment of social phobia. Riva G, Botella C, Legeron P, Optale G, editors. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:91-120. Amsterdam. Ios Press.
Knaevelsrud C, Maercker A. Does the quality of the working alliance predict treatment outcome in online psychotherapy for traumatized patients?. Journal of Medical Internet Research. 2006;8:e31. [pmid: 17213049].
Knaevelsrud C, Maercker A. Long-term effects of an Internet-based treatment for posttraumatic stress. Cognitive Behaviour Therapy. 2010;39:72-77. [pmid: 19675958].
Knaevelsrud C, Wagner B, Karl A, Mueller J. New treatment approaches: Integrating new media in the treatment of war and torture victims. Torture. 2007;17:67-78. [pmid: 17728484].
Knealing TW, Wong CJ, Diemer KN, Hampton J, Silverman K. A randomized controlled trial of the therapeutic workplace for community methadone patients: A partial failure to engage. Experimental and Clinical Psychopharmacology. 2006;14:350-360. [pmid: 16893278].
Kobak KA, Greist JH, Jefferson JW, Mundt JC, Katzelnick DJ. Computerized assessment of depression and anxiety over the telephone using interactive voice response. MD Computing. 1999;16:64-68. [pmid: 10439605].
Kobak KA, Taylor LH, Dottl SL, Greist JH, Jefferson JW, Burroughs D, Serlin RC. A computer-administered telephone interview to identify mental disorders. JAMA. 1997;278:905-910. [pmid: 9302242].
Kobak KA, Williams JB, Engelhardt N. A comparison of face-to-face and remote assessment of inter-rater reliability on the Hamilton Depression Rating Scale via videoconferencing. Psychiatry Research. 2008;158:99-103. [pmid: 17961715].
Koch EF. The VA Maryland Health Care System's telemental health program. Psychological Services. 2012;9:203-205. [pmid: 22662735].
Koivunen M, Hätönen H, Välimäki M. Barriers and facilitators influencing the implementation of an interactive Internet-portal application for patient education in psychiatric hospitals. Patient Education and Counseling. 2008;70:412-419. [pmid: 18079085].
Koivunen M, Välimäki M, Patel A, Knapp M, Hätönen H, Kuosmanen L, Katajisto J. Effects of the implementation of the Web-based patient support system on staff's attitudes towards computers and IT use: A randomised controlled trial. Scandinavian Journal of Caring Sciences. 2010;24:592-599. [pmid: 20409064].
Kontos EZ, Bennett GG, Viswanath K. Barriers and facilitators to home computer and Internet use among urban novice computer users of low socioeconomic position. Journal of Medical Internet Research. 2007;9:e31. [pmid: 17951215].
Koonce TY, Giuse DA, Beauregard JM, Giuse NB. Toward a more informed patient: Bridging health care information through an interactive communication portal. Journal of the Medical Library Association. 2007;95:77-81. [pmid: 17252070].
Kopel H, Nunn K, Dossetor D. Evaluating satisfaction with a child and adolescent psychological telemedicine outreach service. Journal of Telemedicine and Telecare. 2001;7(Suppl 2):35-40. [pmid: 11747654].
Koski-Jannes A, Cunningham JA, Tolonen K, Bothas H. Internet-based self-assessment of drinking—3-month follow-up data. Addictive Behaviors. 2007;32:533-542. [pmid: 16822619].
Kosma M, Cardinal BJ, McCubbin JA. A pilot study of a Web-based physical activity motivational program for adults with physical disabilities. Disability and Rehabilitation. 2005;27:1435-1442. [pmid: 16418058].
Kotz D, Avancha S, Baxi A. A privacy framework for mobile health and home-care systems. Proceedings of the first ACM workshop on security and privacy in medical and home-care systems. 2009:1-12. New York. Association for Computing Machinery.
Kraaij V, van Emmerik A, Garnefski N, Schroevers MJ, Lo-Fo-Wong D, van Empelen P, Maes S. Effects of a cognitive behavioral self-help program and a computerized structured writing intervention on depressed mood for HIV-infected people: A pilot randomized controlled trial. Patient Education and Counseling. 2010;80:200-204. [pmid: 19781889].
Kramer GM, Mishkind MC, Luxton DD. Managing risk and protecting privacy in telemental health: An overview of legal, regulatory, and risk management issues. Myers K, Turvey CL, editors. Telemental health: Clinical, technical, and administrative foundations for evidence-based practice. 2012:83-108. London. Elsevier Science.
Kramer GM, Shore JH, Mishkind MC, Friedl KE, Poropatich RK, Gahm GA. A standard telemental health evaluation model: The time is now. Telemedicine Journal and e-Health. 2012;18:309-313. New York. Elsevier Science. [pmid: 22424077].
Kraus R, Zack JS. The business aspects of online counseling. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:145-160. New York. Elsevier Science.
Kraus R. Ethical and legal considerations for providers of mental health services online. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:123-144. New York. Elsevier Science.
Kraus R, Zack JS, Stricker G. 2004. Online counseling: A handbook for mental health professionals. Amsterdam. Elsevier Academic Press.
Kuhn E, Greene C, Hoffman J, Nguyen T, Wald L, Schmidt J, Ruzek J. Preliminary evaluation of PTSD Coach, a smartphone app for post-traumatic stress symptoms. Military Medicine. 2014;179:12-18. [pmid: 24402979].
Kurtz MM, Baker E, Pearlson GD, Astur RS. A virtual reality apartment as a measure of medication management skills in patients with schizophrenia: A pilot study. Schizophrenia Bulletin. 2007;33:1162-1170. [pmid: 16956984].
Kypri K, Hallett J, Howat P, McManus A, Maycock B, Bowe S, Horton NJ. Randomized controlled trial of proactive Web-based alcohol screening and brief intervention for university students. Archives of Internal Medicine. 2009;169:1508-1514. [pmid: 19752409].
Kypri K, McAnally HM. Randomized controlled trial of a Web-based primary care intervention for multiple health risk behaviors. Preventive Medicine. 2005;41:761-766. [pmid: 16120456].
Kypri K, Saunders JB, Williams SM, McGee RO, Langley JD, Cashell-Smith ML, Gallagher SJ. Web-based screening and brief intervention for hazardous drinking: A double-blind randomized controlled trial. Addiction. 2004;99:1410-1417. [pmid: 15500594].
L'Abate L. Taking the bull by the horns: Beyond talk in psychological interventions. Family Journal: Counseling and Therapy for Couples and Families. 1999;7:206-220.
L'Abate L, Kaiser DA. 2011. Handbook of technology in psychology, psychiatry and neurology theory, research, and practice. Hauppauge, NY. Nova Science Publishers.
Lack CW, Storch EA. The use of computers in the assessment and treatment of obsessive-compulsive disorder. Computers in Human Behavior. 2008;24:917-929.
Lambert MV, Senior C, Phillips ML, David AS. Depersonalization in cyberspace. Journal of Nervous and Mental Disease. 2000;188:764-771. [pmid: 11093379].
LaMendola WF. 2000. Telemental health services in frontier areas: Provider and consumer perspectives. Letter to the field no. 19. Boulder, CO. Western Interstate Commission for Higher Education.
LaMendola WF, Krysik J. Design imperatives to enhance evidence-based interventions with persuasive technology: A case scenario in preventing child maltreatment. Journal of Technology in Human Services. 2008;26:397-422.
Landau BM. Psychotherapy online in 2001: For psychotherapists new to the Internet. Journal of Mental Imagery. 2001;25:65-82.
Landau J, Garrett J, Webb R. Assisting a concerned person to motivate someone experiencing cybersex into treatment: Application of invitational intervention: The ARISE Model to cybersex. Journal of Marital and Family Therapy. 2008;34:498-511. [pmid: 19017188].
Landback J, Prochaska M, Ellis J, Dmochowska K, Kuwabara SA, Gladstone T, Van Voorhees BW. From prototype to product: Development of a primary care/internet based depression prevention intervention for adolescents (CATCH-IT). Community Mental Health Journal. 2009;45:349-354. [pmid: 19641992].
Lane DJ, Lindemann DF, Schmidt JA. A comparison of computer-assisted and self-management programs for reducing alcohol use among students in first year experience courses. Journal of Drug Education. 2012;42:119-135. [pmid: 23185834].
Lange A, Rietdijk D, Hudcovicova M, van de Ven J-P, Schrieken B, Emmelkamp PM. Interapy: A controlled randomized trial of the standardized treatment of posttraumatic stress through the Internet. Journal of Consulting and Clinical Psychology. 2003;71:901-909. [pmid: 14516238].
Lange A, van de Ven J-P, Schrieken BA, Bredeweg B, Emmelkamp PM. Internet-mediated, protocol-driven treatment of psychological dysfunction. Journal of Telemedicine and Telecare. 2000;6:15-21. [pmid: 10824385].
Lau JT, Lau M, Cheung A, Tsui HY. A randomized controlled study to evaluate the efficacy of an Internet-based intervention in reducing HIV risk behaviors among men who have sex with men in Hong Kong. AIDS Care. 2008;20:820-828. [pmid: 18608057].
Lauder S, Chester A, Castle D, Dodd S, Berk L, Klein B, Berk M. Development of an online intervention for bipolar disorder. www.moodswings.net.au. Psychology Health & Medicine. 2013;18(2):155-165.
Laursen D. Counseling young cannabis users by text message. Journal of Computer-Mediated Communication. 2010;15:646-665.
Layne CM, Hohenshil TH. High tech counseling: Revisited. Journal of Counseling & Development. 2005;83:222-226.
Lazev A, Vidrine D, Arduino R, Gritz E. Increasing access to smoking cessation treatment in a low-income, HIV-positive population: The feasibility of using cellular telephones. Nicotine and Tobacco Research. 2004;6:281-286. [pmid: 15203801].
Le HN, Perry DF, Sheng X. Using the Internet to screen for postpartum depression. Maternal and Child Health Journal. 2009;13:213-221. [pmid: 18278545].
Leach LS, Christensen H. A systematic review of telephone-based interventions for mental disorders. Journal of Telemedicine and Telecare. 2006;12:122-129. [pmid: 16638233].
Leach LS, Christensen H, Griffiths KM, Jorm AF, Mackinnon AJ. Websites as a mode of delivering mental health information: Perceptions from the Australian public. Social Psychiatry and Psychiatric Epidemiology. 2007;42:167-172. [pmid: 17160594].
Learmonth D, Rai S. Taking computerized CBT beyond primary care. British Journal of Clinical Psychology. 2008;47:111-118. [pmid: 17939879].
Leary PS. Technology and the continuing education of professional counselors. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:291-301. Alexandria, VA. American Counseling Association.
Lebow J. Not just talk, maybe some risk: The therapeutic potentials and pitfalls of computer-mediated conversation. Journal of Marital and Family Therapy. 1998;24:203-206. [pmid: 9583059].
Lee C. Cybercounseling and empowerment: Bridging the digital divide. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: Strategies and resources for the millennium. 2000:85-93. Alexandria, VA. American Counseling Association.
Lee CJ, Hornik RC. Physician trust moderates the Internet use and physician visit relationship. Journal of Health Communication. 2009;14:70-76. [pmid: 19180372].
Lee CM, Neighbors C, Kilmer JR, Larimer ME. A brief, Web-based personalized feedback selective intervention for college student marijuana use: A randomized clinical trial. Psychology of Addictive Behaviors. 2010;24:265-273. [pmid: 20565152].
Lee J, Lim Y, Graham SJ, Kim G, Wiederhold BK, Wiederhold MD, Kim SI. Nicotine craving and cue exposure therapy by using virtual environments. CyberPsychology & Behavior. 2004;7:705-713. [pmid: 15687806].
Lee JH, Kwon H, Choi J, Yang BH. Cue-exposure therapy to decrease alcohol craving in virtual environment. CyberPsychology & Behavior. 2007;10:617-623. [pmid: 17927528].
Lefebvre A. All we need to fear is fear itself: Overcoming the Internet resistance of child psychiatrists. CyberPsychology & Behavior. 2000;3:951-957.
Lehavot K, Barnett JE, Powers D. Psychotherapy, professional relationships, and ethical considerations in the Myspace generation. Professional Psychology: Research and Practice. 2010;41:160-166.
Leibert T, Archer J Jr., Munson J, York G. An exploratory study of client perceptions of Internet counseling and the therapeutic alliance. Journal of Mental Health Counseling. 2006;28:69-83.
Lemire M, Sicotte C, Pare G. Internet use and the logics of personal empowerment in health. Health Policy. 2008;88:130-140. [pmid: 18436330].
Lenert L, Muñoz RF, Perez JE, Bansod A. Automated e-mail messaging as a tool for improving quit rates in an Internet smoking cessation intervention. Journal of the American Medical Informatics Association. 2004;11:235-240. [pmid: 15064291].
Lenert L, Muñoz RF, Stoddard J, Delucchi K, Bansod A, Skoczen S, Pérez-Stable EJ. Design and pilot evaluation of an Internet smoking cessation program. Journal of the American Medical Informatics Association. 2003;10:16-20. [pmid: 12509354].
Lenhart A. 2009. Adults and social network Websites. Washington, DC. Pew Research Center.
Lenhart A. 2009. The democratization of online social networks. Washington, DC. Pew Research Center.
Lenhart A. 2009. Social networks grow: Friending mom and dad. Washington, DC. Pew Research Center.
Leong KC, Chen WS, Leong KW, Mastura I, Mimi O, Sheikh MA, Teng CL. The use of text messaging to improve attendance in primary care: A randomized controlled trial. Family Practice. 2006;23:699-705. [pmid: 16916871].
Lessler JT, Caspar RA, Penne MA, Barker PR. Developing computer assisted interviewing (CAI) for the National Household Survey on Drug Abuse. Journal of Drug Issues. 2000;30:9-34.
Lester D. E-therapy: Caveats from experiences with telephone therapy. Psychological Reports. 2006;99:894-896. [pmid: 17305208].
Lester D. The use of the Internet for counseling the suicidal individual: Possibilities and drawbacks. Omega (Westport). 2008;58:233-250. [pmid: 19320294].
Leung SF, French P, Chui C, Arthur D. Computerized mental health assessment in integrative health clinics: A cross-sectional study using structured interview. International Journal of Mental Health Nursing. 2007;16:441-446. [pmid: 17995515].
Leung SF, Ma J, Russell J. Breaking the silence of eating disorders with the hope of an online self-help programme. Contemporary Nurse. 2012;40:245-257. [pmid: 22554217].
Leusink PM, Aarts E. Treating erectile dysfunction through electronic consultation: A pilot study. Journal of Sex and Marital Therapy. 2006;32:401-407. [pmid: 16959663].
Levin W, Campbell DR, McGovern KB, Gau JM, Kosty DB, Seeley JR, Lewinsohn PM. A computer-assisted depression intervention in primary care. Psychological Medicine. 2011;41:1373-1383. [pmid: 20961474].
Levine D, Madsen A, Wright E, Barar RE, Santelli J, Bull S. Formative research on MySpace: Online methods to engage hard-to-reach populations. Journal of Health Communication. 2011;16:448-454. [pmid: 21391040].
Levine J. INTERNET: A framework for analyzing online human service practices. Journal of Technology in Human Services. 2000;17:173-192.
Lewis G, Sharp D, Bartholomew J, Pelosi AJ. Computerized assessment of common mental disorders in primary care: Effect on clinical outcome. Family Practice. 1996;13:120-126. [pmid: 8732321].
Lewis MA, Neighbors C, Oster-Aaland L, Kirkeby BS, Larimer ME. Indicated prevention for incoming freshmen: Personalized normative feedback and high-risk drinking. Addictive Behaviors. 2007;32:2495-2508. [pmid: 17658695].
Leykin Y, Barrera AZ, Muñoz RF. Smoking cessation via the Internet. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:109-132. New York. Routledge/Taylor & Francis Group.
Leykin Y, Muñoz RF, Contreras O. Are consumers of Internet health information “cyberchondriacs”? Characteristics of 24,965 users of a depression screening site. Depression and Anxiety. 2012;29:71-77. [pmid: 21681872].
Lichtenstein E, Glasgow RE, Lando HA, Ossip-Klein DJ, Boles SM. Telephone counseling for smoking cessation: Rationales and meta-analytic review of evidence. Health Education Research. 1996;11:243-257. [pmid: 10163409].
Lieberman DZ. Internet facilitation of opioid dependence. American Journal on Addictions. 2001;10:279-281. [pmid: 11579626].
Lieberman DZ. An automated treatment for jet lag delivered through the Internet. Psychiatric Services. 2003;54:394-396. [pmid: 12610250].
Lieberman DZ. Clinical characteristics of individuals using an online alcohol evaluation program. American Journal of Addiction. 2005;14:155-165.
Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. CyberPsychology & Behavior. 2006;9:603-607. [pmid: 17034328].
Lieberman DZ, Huang SW. A technological approach to reaching a hidden population of problem drinkers. Psychiatric Services. 2008;59:297-303. [pmid: 18308911].
Lieberman DZ, Kelly TF, Douglas L, Goodwin FK. A randomized comparison of online and paper mood charts for people with bipolar disorder. Journal of Affective Disorders. 2010;124:85-89. [pmid: 19896202].
Lieberman DZ, Massey SH. Pathways to change: The effect of a Web application on treatment interest. American Journal of Addiction. 2008;17:265-270.
Lieberman MA, Winzelberg A, Golant M, Wakahiro M, DiMinno M, Aminoff M, Christine C. Online support groups for Parkinson's patients: A pilot study of effectiveness. Social Work in Health Care. 2005;42:23-38. [pmid: 16390834].
Liebowitz J. Teaching people skills totally online?. College Teaching. 2003;51:82-85.
Lim MSC, Hocking JS, Hellard ME, Aitken CK. SMS STI A review of the uses of mobile phone text messaging in sexual health. International Journal of STD & AIDS. 2008;19:287-290. [pmid: 18482956].
Lin CC, Bai Y, Chen JY. Reliability of information provided by patients of a virtual psychiatric clinic. Psychiatric Services. 2003;54:1167-1168. [pmid: 12883154].
Lin J-L, Vahabzadeh M, Mezghanni M, Epstein DH, Preston KL. A high-level specification for adaptive ecological momentary assessment: Real-time assessment of drug craving, use and abstinence. AMIA Annual Symposium Proceedings. 2005:455-459. Retrieved November 5, 2015 from http://www.ncbi.nlm.nih.gov/pmc/articles/PMC1560797.
Lindenberg K, Moessner M, Harney J, McLaughlin O, Bauer S. E-health for individualized prevention of eating disorders. Clinical Practice & Epidemiology in Mental Health. 2011;7:74-83. [pmid: 21687562].
Link MW, Mokdad AH. Effects of survey mode on self-reports of adult alcohol consumption: A comparison of mail, Web and telephone approaches. Journal of Studies on Alcohol. 2005;66:239-245. [pmid: 15957675].
Linke S, Brown A, Wallace P. Down your drink: A Web-based intervention for people with excessive alcohol consumption. Alcohol and Alcoholism. 2004;39:29-32. [pmid: 14691071].
Linke S, McCambridge J, Khadjesari Z, Wallace P, Murray E. Development of a psychologically enhanced interactive online intervention for hazardous drinking. Alcohol and Alcoholism. 2008;43:669-674. [pmid: 18693217].
Linke S, Murray E, Butler C, Wallace P. Internet-based interactive health intervention for the promotion of sensible drinking: Patterns of use and potential impact on members of the general public. Journal of Medical Internet Research. 2007;9:e10. [pmid: 17513281].
Lintvedt OK, Sorensen K, Ostvik AR, Verplanken B, Wang CE. The need for Web-based cognitive behavior therapy among university students. Journal of Technology in Human Services. 2008;26:239-258.
Lipman EL, Kenny M, Marziali E. Providing Web-based mental health services to at-risk women. BMC Women's Health. 2011;11:38. [pmid: 21854563].
Lissman TL, Boehnlein JK. A critical review of Internet information about depression. Psychiatric Services. 2001;52:1046-1050. [pmid: 11474049].
Lissman TL, Boehnlein JK. Health information on the Internet. Psychiatric Services. 2002;53:348. [pmid: 11875239].
Litz B. How “supportive” is Internet-based supportive psychotherapy?: Reply. American Journal of Psychiatry. 2008;165:534-535. [pmid: 18381918].
Litz BT, Engel CC, Bryant RA, Papa A. A randomized, controlled proof-of-concept trial of an Internet-based, therapist-assisted self-management treatment for posttraumatic stress disorder. American Journal of Psychiatry. 2007;164:1676-1683. [pmid: 17974932].
Ljotsson B, Falk L, Vesterlund AW, Hedman E, Lindfors P, Ruck C, Andersson G. Internet-delivered exposure and mindfulness based therapy for irritable bowel syndrome: A randomized controlled trial. Behaviour Research and Therapy. 2010;48:531-539. [pmid: 20362976].
Ljotsson B, Lundin C, Mitsell K, Carlbring P, Ramklint M, Ghaderi A. Remote treatment of bulimia nervosa and binge eating disorder: A randomized trial of Internet-assisted cognitive behavioural therapy. Behaviour Research and Therapy. 2007;45:649-661. [pmid: 16899213].
Lo B, Parham L. The impact of Web 2.0 on the doctor-patient relationship. Journal of Law, Medicine and Ethics. 2010;38:17-26.
Long AC, Palermo TM. Brief report: Web-based management of adolescent chronic pain: Development and usability testing of an online family cognitive behavioral therapy program. Journal of Pediatric Psychology. 2009;34:511-516. [pmid: 18669578].
Long JD, Stevens KR. Using technology to promote self-efficacy for healthy eating in adolescents. Journal of Nursing Scholarship. 2004;36:134-139. [pmid: 15227760].
Looi J, Raphael B. Reflections on therapy in the era of the Internet. Australasian Psychiatry. 2007;15:334-337. [pmid: 17612889].
Lord S, Brevard J, Budman S. Connecting to young adults: An online social network survey of beliefs and attitudes associated with prescription opioid misuse among college students. Substance Use & Misuse. 2011;46:66-76. [pmid: 21190407].
Lorian CN, Titov N, Grisham JR. Changes in risk-taking over the course of an Internet-delivered cognitive behavioral therapy treatment for generalized anxiety disorder. Journal of Anxiety Disorders. 2012;26:140-149. [pmid: 22079215].
Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: A randomized trial. Medical Care. 2006;44:964-971. [pmid: 17063127].
Lovecchio CP, Wyatt TM, DeJong W. Reductions in drinking and alcohol-related harms reported by first-year college students taking an online alcohol education course: A randomized trial. Journal of Health Communication. 2010;15:805-819. [pmid: 21104507].
Lovejoy TI, Demireva PD, Grayson JL, McNamara JR. Advancing the practice of online psychotherapy: An application of Rogers' diffusion of innovations theory. Psychotherapy: Theory, Research, Practice, Training. 2009;46:112-124.
Lovell K, Bee P. Optimising treatment resources for OCD: A review of the evidence base for technology-enhanced delivery. Journal of Mental Health. 2011;20:525-542. [pmid: 22126631].
Lovell K, Fullalove L, Garvey R, Brooker C. Telephone treatment of obsessive–compulsive disorder. Behavioural and Cognitive Psychotherapy. 2000;28:87-91.
Low KG, Charanasomboon S, Lesser J, Reinhalter K, Martin R, Jones H, Taylor CB. Effectiveness of a computer-based interactive eating disorders prevention program at long-term follow-up. Eating Disorders: The Journal of Treatment & Prevention. 2006;14:17-30.
Lubans DR, Morgan PJ, Callister R, Collins CE. Effects of integrating pedometers, parental materials, and e-mail support within an extracurricular school sport intervention. Journal of Adolescent Health. 2009;44:176-183. [pmid: 19167667].
Luce KH, Winzelberg AJ, Zabinski MF, Osborne MI. Internet-delivered psychological interventions for body image dissatisfaction and disordered eating. Psychotherapy: Theory, Research, Practice, Training. 2003;40:148-154.
Lucey R. 2015. SAMHSA's Current and Future Direction for Prevention in Higher Education. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Ludman EJ, Simon GE, Tutty S, Von Korff M. A randomized trial of telephone psychotherapy and pharmacotherapy for depression: Continuation and durability of effects. Journal of Consulting and Clinical Psychology. 2007;75:257-266. [pmid: 17469883].
Lustria ML, Cortese J, Noar SM, Glueckauf RL. Computer-tailored health interventions delivered over the Web: Review and analysis of key components. Patient Education and Counseling. 2009;74:156-173. [pmid: 18947966].
Luxton DD, Armstrong CM, Fantelli EE, Thomas EK. Attitudes and awareness of Web-based self-care resources in the military: A preliminary survey study. Telemedicine and e-Health. 2011;17:580-583. [pmid: 21718091].
Luxton DD, June JD, Kinn JT. Technology-based suicide prevention: Current applications and future directions. Telemedicine and e-Health. 2011;17:50-54. [pmid: 21214382].
Luxton DD, Kinn JT, June JD, Pierre LW, Reger MA, Gahm GA. Caring letters project: A military suicide-prevention pilot program. Crisis. 2012;33:5-12. [pmid: 21940244].
Luxton DD, Mishkind MC, Crumpton RM, Ayers TD, Mysliwiec V. Usability and feasibility of smartphone video capabilities for telehealth care in the U.S. military. Telemedicine and e-Health. 2012;18:409-412. [pmid: 22650351].
Luxton DD, O'Brien K, McCann RA, Mishkind MC. Home-based telemental healthcare safety planning: What you need to know. Telemedicine and e-Health. 2012;18:629-633. [pmid: 23061644].
Luxton DD, Sirotin AP, Mishkind MC. Safety of telemental healthcare delivered to clinically unsupervised settings: A systematic review. Telemedicine and e-Health. 2010;16:705-711. [pmid: 20583951].
Macedonia M. Virtual worlds: A new reality for treating post-traumatic stress disorder. IEEE Computer Graphics and Application. 2009;29:86-88.
MacGregor AD, Hayward L, Peck DF, Wilkes P. Empirically grounded clinical interventions: Clients' and referrers' perceptions of computer-guided CBT (FearFighter). Behavioural and Cognitive Psychotherapy. 2009;37:1-9. [pmid: 19364403].
Mackert M, Whitten P, Garcia A. Interventions for low health literate audiences. Journal of Computer-Mediated Communication. 2008;13:504-515.
Mackinnon A, Griffiths KM, Christensen H. Comparative randomised trial of online cognitive–behavioural therapy and an information Website for depression: 12-month outcomes. British Journal of Psychiatry. 2008;192:130-134. [pmid: 18245031].
MacLeod C, Mathews A. Cognitive bias modification approaches to anxiety. Annual Review of Clinical Psychology. 2012;8:189-217.
MacLeod C, Soong LY, Rutherford EM, Campbell LW. Internet-delivered assessment and manipulation of anxiety-linked attentional bias: Validation of a free-access attentional probe software package. Behavior Research Methods. 2007;39:533-538. [pmid: 17958165].
Madell DE, Muncer SJ. Control over social interactions: An important reason for young people's use of the Internet and mobile phones for communication?. CyberPsychology & Behavior. 2007;10:137-140. [pmid: 17305461].
Magaletta PR, Fagan TJ, Peyrot MF. Telehealth in the Federal Bureau of Prisons: Inmates' perceptions. Professional Psychology: Research and Practice. 2000;31:497-502.
Magee JC, Ritterband LM, Thorndike FP, Cox DJ, Borowitz SM. Exploring the relationship between parental worry about their children's health and usage of an Internet intervention for pediatric encopresis. Journal of Pediatric Psychology. 2009;34:530-538. [pmid: 18772228].
Maheu MM. Exposing the risk, yet moving forward: A behavioral e-health model. Journal of Computer Mediated Communication. 2001;6(4):0.
Maheu MM. The online clinical practice management model. Psychotherapy: Theory, Research, Practice, Training. 2003;40:20-32.
Maheu MM, Gordon BL. Counseling and therapy on the Internet. Professional Psychology: Research and Practice. 2000;31:484-489.
Maheu M, McMenamin J. 2013. Telepsychology best practices. Koocher G, Norcross J, Greene B, editors. Psychologist's desk reference. 3rd ed. New York. Oxford University Press.
Maheu MM, Pulier ML, Roy S. 2013. Finding, evaluating and using smartphone applications. Koocher G, Norcross J, Greene B, editors. Psychologist's desk reference. 3rd ed. New York. Oxford University Press Publication.
Maheu MM, Pulier ML, Wilhelm FH, McMenamin JP, Brown-Connolly NE. 2004. The mental health professional and the new technologies: A handbook for practice today. Mahwah, NJ. Lawrence Erlbaum Associates.
Maheu MM, Whitten P, Allen A. 2001. E-health, telehealth, and telemedicine: A guide to start-up and success. San Francisco. Jossey-Bass.
Maheu MM, Whitten P, Allen A. Medicolegal liability: E-mail and other considerations; Guidelines for patient communications. Behavioral Health Management. 2001;21:44-46.
Mains JA, Scogin FR. The effectiveness of self-administered treatments: A practice-friendly review of the research. Journal of Clinical Psychology. 2003;59:237-246. [pmid: 12552632].
Malater E. Caught in the Web: Patient, therapist, e-mail, and the Internet. Psychoanalytic Review. 2007;94:151-168. [pmid: 17367281].
Mallen M. Online counseling research. Kraus R, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:69-89. New York. Elsevier Science.
Mallen MJ, Blalock JA, Cinciripini PM. Using technology to serve patients and practitioners: A comprehensive tobacco-cessation program for cancer patients. Counselling and Psychotherapy Research: Linking Research with Practice. 2006;6:196-201.
Mallen MJ, Day SX, Green MA. Online versus face-to-face conversation: An examination of relational and discourse variables. Psychotherapy: Theory, Research, Practice, Training. 2003;40:155-163.
Mallen MJ, Vogel DL. Introduction to the major contribution: Counseling psychology and online counseling. Counseling Psychologist. 2005;33:761-775.
Mallen MJ, Vogel DL. Online counseling: A need for discovery. Counseling Psychologist. 2005;33:910-921.
Mallen MJ, Vogel DL, Rochlen AB. The practical aspects of online counseling: Ethics, training, technology, and competency. Counseling Psychologist. 2005;33:776-818.
Mallen MJ, Vogel DL, Rochlen AB, Day SX. Online counseling: Reviewing the literature from a counseling psychology framework. Counseling Psychologist. 2005;33:819-871.
Manchanda M, McLaren P. Cognitive behaviour therapy via interactive video. Journal of Telemedicine and Telecare. 1998;4(Suppl 1):53-55. [pmid: 9640736].
Manfredo IT. The role of organizational commitment in practitioner implementation of evidence-based practices in substance abuse treatment settings. Dissertation Abstracts International, A: The Humanities and Social Sciences. 2010;71:1796.
Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Education Research. 2007;22:1-13. [pmid: 16714366].
Manhal-Baugus M. E-therapy: Practical, ethical, and legal issues. CyberPsychology & Behavior. 2001;4:551-563. [pmid: 11725648].
Manring J, Greenberg RP, Gregory R, Gallinger L. Learning psychotherapy in the digital age. Psychotherapy. 2011;48:119-126. [pmid: 21639655].
Mansell P, Read J. Posttraumatic stress disorder, drug companies, and the Internet. Journal of Trauma and Dissociation. 2009;10:9-23. [pmid: 19197709].
Manwaring JL, Bryson SW, Goldschmidt AB, Winzelberg AJ, Luce KH, Cunning D, Taylor CB. Do adherence variables predict outcome in an online program for the prevention of eating disorders?. Journal of Consulting and Clinical Psychology. 2008;76:341-346. [pmid: 18377129].
Mar CM, Chabal C, Anderson RA, Vore AE. An interactive computer tutorial to teach pain assessment. Journal of Health Psychology. 2003;8:161-173. [pmid: 22113908].
March S, Spence SH, Donovan CL. The efficacy of an Internet-based cognitive-behavioral therapy intervention for child anxiety disorders. Journal of Pediatric Psychology. 2009;34:474-487. [pmid: 18794187].
Marko M, Fogel J, Mykerezi E, Van Voorhees BW. Adolescent Internet depression prevention: Preferences for intervention and predictors of intentions and adherence. Journal of CyberTherapy and Rehabilitation. 2010;3:9-30.
Markowitz JC. How “supportive” is Internet-based supportive psychotherapy?. American Journal of Psychiatry. 2008;165:534. [pmid: 18381918].
Marks IM. Computer aids to mental health care. Canadian Journal of Psychiatry/Revue Canadienne de Psychiatrie. 1999;44:548-555. [pmid: 10497696].
Marks IM, Baer L, Greist JH, Park JM, Bachofen M, Nakagawa A, Mantle JM. Home self-assessment of obsessive–compulsive disorder. Use of a manual and a computer-conducted telephone interview: Two UK–US studies. British Journal of Psychiatry. 1998;172:406-412. [pmid: 9747402].
Marks IM, Cavanagh K. Computer-aided psychological treatments: Evolving issues. Annual Review of Clinical Psychology. 2009;5:121-141.
Marks IM, Cavanagh K, Gega L. Computer-aided psychotherapy: Revolution or bubble?. British Journal of Psychiatry. 2007;191:471-473. [pmid: 18055948].
Marks IM, Kenwright M, McDonough M, Whittaker M, Mataix-Cols D. Saving clinicians' time by delegating routine aspects of therapy to a computer: A randomized controlled trial in phobia/panic disorder. Psychological Medicine. 2004;34:9-17. [pmid: 14971623].
Marks IM, Mataix-Cols D, Kenwright M. “Saving clinician's time by delegating routine aspects of therapy to a computer: A randomized controlled trial in phobia/panic disorder”: Reply. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2005;35:150-151.
Marks IM, Shaw S, Parkin R. Computer-aided treatments of mental health problems. Clinical Psychology: Science and Practice. 1998;5:151-170.
Marsch LA. 2011. Computer delivered psychosocial treatment for substance use disorders. Neurobiological and Technological Mechanisms To Improve the Efficacy and Effectiveness of Substance Abuse Treatment Symposium conducted at American Psychological Association Annual Meeting. Washington, DC.
Marsch LA. Technology-based interventions targeting substance use disorders and related issues: An editorial. Substance Use & Misuse. 2011;46:1-3. [pmid: 21190400].
Marsch LA, Bickel WK. Efficacy of computer-based HIV/AIDS education for injection drug users. American Journal of Health Behavior. 2004;28:316-327. [pmid: 15228968].
Marsch LA, Bickel WK, Badger GJ. Applying computer technology to substance abuse prevention science: Results of a preliminary examination. Journal of Child & Adolescent Substance Abuse. 2007;16:69-94.
Marsch LA, Grabinski MJ, Bickel WK, Desrosiers A, Guarino H, Muehlbach B, Acosta M. Computer-assisted HIV prevention for youth with substance use disorders. Substance Use & Misuse. 2011;46:46-56. [pmid: 21190405].
Marsch LA, Guarino H, Acosta M, Aponte-Melendez Y, Cleland C, Grabinski M, Edwards J. Web-based behavioral treatment for substance use disorders as a partial replacement of standard methadone maintenance treatment. Journal of Substance Abuse Treatment. 2014;46:43-51. [pmid: 24060350].
Martin-Khan M, Wootton R, Gray L. A systematic review of the reliability of screening for cognitive impairment in older adults by use of standardised assessment tools administered via the telephone. Journal of Telemedicine and Telecare. 2010;16:422-428. [pmid: 21030488].
Martino S, Brigham GS, Higgins C, Gallon S, Freese TE, Albright LM, Condon TP. Partnerships and pathways of dissemination: The National Institute on Drug Abuse–Substance Abuse and Mental Health Services Administration Blending Initiative in the Clinical Trials Network. Journal of Substance Abuse Treatment. 2010;38:S31-S43. [pmid: 20307793].
Marziali E, Donahue P. Caring for others: Internet video-conferencing group intervention for family caregivers of older adults with neurodegenerative disease. Gerontologist. 2006;46:398-403. [pmid: 16731880].
Masi D, Freedman M. The use of telephone and on line technology in assessment, counseling, and therapy. Employee Assistance Quarterly. 2001;16:49-63.
Mataix-Cols D, Cameron R, Gega L, Kenwright M, Marks IM. Effect of referral source on outcome with cognitive-behavior therapy self-help. Comprehensive Psychiatry. 2006;47:241-245. [pmid: 16769296].
Matano RA, Koopman C, Wanat SF, Winzelberg AJ, Whitsell SD, Westrup D, Taylor CB. A pilot study of an interactive Web site in the workplace for reducing alcohol consumption. Journal of Substance Abuse Treatment. 2007;32:71-80. [pmid: 17175400].
Mathews A, Ridgeway V, Cook E, Yiend J. Inducing a benign interpretational bias reduces trait anxiety. Journal of Behavior Therapy and Experimental Psychiatry. 2007;38:225-236. [pmid: 17141179].
Maust DT, Mavandadi S, Benson A, Streim JE, Difilippo S, Snedden T, Oslin DW. Telephone-based care management for older adults initiated on psychotropic medication. International Journal of Geriatric Psychiatry. 2012;28(4):410-416. [pmid: 22678956].
Maust DT, Mavandadi S, Eakin A, Streim JE, Difillipo S, Snedden T, Oslin DW. Telephone-based behavioral health assessment for older adults starting a new psychiatric medication. American Journal of Geriatric Psychiatry. 2011;19:851-858. [pmid: 21946801].
Mays J. Online counseling—Is it too remote?. Counselor. 2008;9:42-43.
Mazzi CP, Kidd M. A framework for the evaluation of Internet-based diabetes management. Journal of Medical Internet Research. 2002;4:e1. [pmid: 11956033].
Mbilinyi LF, Neighbors C, Walker DD, Roffman RA, Zegree J, Edleson J, O'Rourke A. A telephone intervention for substance-using adult male perpetrators of intimate partner violence. Research on Social Work Practice. 2011;21:43-56. [pmid: 22754270].
McAdams CR III, Wyatt KL. The regulation of technology-assisted distance counseling and supervision in the United States: An analysis of current extent, trends, and implications. Counselor Education and Supervision. 2010;49:179-192.
McCabe M, Price E. Internet-based psychological and oral medical treatment compared to psychological treatment alone for ED. Journal of Sexual Medicine. 2008;5:2338-2346. [pmid: 18554261].
McCabe MP, Price E. Attrition from an Internet-based psychological intervention for erectile dysfunction: Who is likely to drop out?. Journal of Sex and Marital Therapy. 2009;35:391-401. [pmid: 20183006].
McCabe MP, Price E, Piterman L, Lording D. Evaluation of an Internet-based psychological intervention for the treatment of erectile dysfunction. International Journal of Impotence Research. 2008;20:324-330. [pmid: 18305485].
McCabe OL, Barnett DJ, Taylor HG, Links JM. Ready, willing, and able: A framework for improving the public health emergency preparedness system. Disaster Medicine and Public Health Preparedness. 2010;4:161-168. [pmid: 20526139].
McCabe SE, Couper MP, Cranford JA, Boyd CJ. Comparison of Web and mail surveys for studying secondary consequences associated with substance use: Evidence for minimal mode effects. Addictive Behaviors. 2006;31:162-168. [pmid: 15916862].
McCambridge J, Thomas BA. Short forms of the AUDIT in a Web-based study of young drinkers. Drug and Alcohol Review. 2009;28:18-24. [pmid: 19320671].
McCarthy DP, Thomas BA. Major MBHOs offer online EAPs. Behavioral Health Management. 2000;20:28-31.
McCarty D, Clancy C. Telehealth: Implications for social work practice. Social Work. 2002;47:153-161. [pmid: 12019802].
McClure JB, Greene SM, Wiese C, Johnson KE, Alexander G, Strecher V. Interest in an online smoking cessation program and effective recruitment strategies: Results from Project Quit. Journal of Medical Internet Research. 2006;8:e14. [pmid: 16954124].
McConnon A, Kirk SF, Ransley JK. Process evaluation of an Internet-based resource for weight control: Use and views of an obese sample. Journal of Nutrition Education and Behavior. 2009;41:261-267. [pmid: 19508931].
McCoy MR, Couch D, Duncan ND, Lynch GS. Evaluating an Internet weight loss program for diabetes prevention. Health Promotion International. 2005;20:221-228. [pmid: 15797900].
McCoyd JLM, Kerson TS. Conducting intensive interviews using email: A serendipitous comparative opportunity. Qualitative Social Work: Research and Practice. 2006;5:389-406.
McCrickard MP, Butler LT. Cybercounseling: A new modality for counselor training and practice. International Journal for the Advancement of Counselling. 2005;27:101-110.
McCullough L, Bhatia M, Ulvenes P, Berggraf L, Osborn K. Learning how to rate video-recorded therapy sessions: A practical guide for trainees and advanced clinicians. Psychotherapy. 2011;48:127-137. [pmid: 21639656].
McDaniel AM, Stratton RM. Internet-based smoking cessation initiatives: Availability, varieties, and likely effects on outcomes. Disease Management & Health Outcomes. 2006;14:275-285.
McDoniel SO, Wolskee P, Shen J. Treating obesity with a novel hand-held device, computer software program, and Internet technology in primary care: The SMART motivational trial. Patient Education and Counseling. 2010;79:185-191. [pmid: 19699049].
McDonnell DD, Kazinets G, Lee HJ, Moskowitz JM. An Internet-based smoking cessation program for Korean Americans: Results from a randomized controlled trial. Nicotine & Tobacco Research. 2011;13:336-343. [pmid: 21330285].
McDowell H, Kim E, Shaw BR, Han JY, Gumieny L. Predictors and effects of training on an online health education and support system for women with breast cancer. Journal of Computer-Mediated Communication. 2010;15:412-426. [pmid: 21949474].
McEvoy PM, Perini SJ. Cognitive behavioral group therapy for social phobia with or without attention training: A controlled trial. Journal of Anxiety Disorders. 2009;23:519-528. [pmid: 19059753].
McFadden J, Jencius M. Using cyberspace to enhance counselors' cultural transcendence. Bloom JW, Walz GR, editors. Cybercounseling and cyberlearning: An encore. 2000:67-84. Alexandria, VA. American Counseling Association.
McGinty KL, Saeed SA, Simmons SC, Yildirim Y. Telepsychiatry and e-mental health services: Potential for improving access to mental health care. Psychiatric Quarterly. 2006;77:335-342. [pmid: 16927161].
McGurk SR, Twamley EW, Sitzer DI, McHugo GJ, Mueser KT. A meta-analysis of cognitive remediation in schizophrenia. American Journal of Psychiatry. 2007;164:1791-1802. [pmid: 18056233].
McIlroy J. Online psychiatry comes into its own. Behavioral Health Management. 2003;23:14-16.
McKay GH, Danaher BG, Seeley RJ, Lichtenstein E, Gau MJ. Comparing two Web-based smoking cessation programs: Randomized controlled trial. Journal of Medical Internet Research. 2008;10:e40. [pmid: 19017582].
McKay JR, Lynch KG, Shepard DS, Morgenstern J, Forman RF, Pettinati HM. Do patient characteristics and initial progress in treatment moderate the effectiveness of telephone-based continuing care for substance use disorders?. Addiction. 2005;100:216-226. [pmid: 15679751].
McKay JR, Lynch KG, Shepard DS, Pettinati HM. The effectiveness of telephone-based continuing care for alcohol and cocaine dependence: 24-month outcomes. Archives of General Psychiatry. 2005;62:199-207. [pmid: 15699297].
McKay JR, Lynch KG, Shepard DS, Ratichek S, Morrison R, Koppenhaver J, Pettinati HM. The effectiveness of telephone-based continuing care in the clinical management of alcohol and cocaine use disorders: 12-month outcomes. Journal of Consulting and Clinical Psychology. 2004;72:967-979. [pmid: 15612844].
McKay JR, Van Horn D, Oslin DW, Ivey M, Drapkin ML, Coviello DM, Lynch KG. Extended telephone-based continuing care for alcohol dependence: 24-month outcomes and subgroup analyses. Addiction. 2011;106:1760-1769. [pmid: 21545667].
McKay JR, Van Horn D, Oslin DW, Lynch KG, Ivey M, Ward K, Coviello DM. A randomized trial of extended telephone-based continuing care for alcohol dependence: Within-treatment substance use outcomes. Journal of Consulting and Clinical Psychology. 2010;78:912-923. [pmid: 20873894].
McKinsey & Co. 1995. Connecting K–12 students to the information superhighway. New York. Author.
McLean CP, Steenkamp MM, Levy HC, Litz BT. Posttraumatic stress disorder. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:45-68. New York. Routledge/Taylor & Francis Group.
McMullan M. Patients using the Internet to obtain health information: How this affects the patient-health professional relationship. Patient Education and Counseling. 2006;63:24-28. [pmid: 16406474].
McNeill LH, Puleo E, Bennett GG, Emmons KM. Exploring social contextual correlates of computer ownership and frequency of use among urban, low-income, public housing adult residents. Journal of Medical Internet Research. 2007;9:e35. [pmid: 18093903].
McPherson TL, Cook RF, Back AS, Hersch RK, Hendrickson A. A field test of a Web-based substance abuse prevention training program for health promotion professionals. American Journal of Health Promotion. 2006;20:396-400. [pmid: 16871819].
McTavish FM, Chih M-Y, Shah D, Gustafson DH. How patients recovering from alcoholism use a smartphone intervention. Journal of Dual Diagnosis. 2012;8(4):294-304. [pmid: 23316127].
Meier A. Technology-mediated groups. Garvin CD, Gutierrez LM, Galinsky MJ, editors. Handbook of social work with groups. 2004:479-503. New York. Guilford Press.
Meier A. In-person counseling and Internet self-help groups: Synthesizing new forms of social work practice. Greif GL, Ephross PH, editors. Group work with populations at risk. 2nd ed. 2005:159-180. New York. Oxford University Press.
Meier A. Integrating in-person counseling and Internet support communities: “Evolving” practice models for social group work with at-risk populations. Integrating in-person counseling and Internet support communities. Greif GL, Ephross PH, editors. Group work with populations at risk. 3rd ed. 2011:170-209. New York. Oxford University Press.
Meites E, Thom DH. Telephone counseling improves smoking cessation rates. American Family Physician. 2007;75:651-652.
Melling B, Houguet-Pincham T. Online peer support for individuals with depression: A summary of current research and future considerations. Psychiatric Rehabilitation Journal. 2011;34:252-254. [pmid: 21208865].
Melville KM, Casey LM, Kavanagh DJ. Dropout from Internet-based treatment for psychological disorders. British Journal of Clinical Psychology. 2010;49:455-471. [pmid: 19799804].
Mensinger JL, Diamond GS, Kaminer Y, Wintersteen MB. Adolescent and therapist perception of barriers to outpatient substance abuse treatment. American Journal of Addiction. 2006;15(Suppl 1):16-25.
Mensinger JL, Lynch KG, TenHave TR, McKay JR. Mediators of telephone-based continuing care for alcohol and cocaine dependence. Journal of Consulting and Clinical Psychology. 2007;75:775-784. [pmid: 17907859].
Merz TA. Using cell/mobile phone SMS for therapeutic intervention. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:29-38. Springfield, IL. Charles C. Thomas Publisher.
Meyer B, Berger T, Caspar F, Beevers GC, Andersson G, Weiss M. Effectiveness of a novel integrative online treatment for depression (Deprexis): Randomized controlled trial. Journal of Medical Internet Research. 2009;11:e15. [pmid: 19632969].
Meyer BC, Clarke CA, Troke TM, Friedman LS. Essential telemedicine elements (tele-ments) for connecting the academic health center and remote community providers to enhance patient care. Academic Medicine. 2012;87:1032-1040. [pmid: 22722348].
Meyerbröker K, Emmelkamp PM. Virtual reality exposure therapy in anxiety disorders: A systematic review of process-and-outcome studies. Depression and Anxiety. 2010;27:933-944. [pmid: 20734361].
Micco N, Gold B, Buzzell P, Leonard H, Pintauro S, Harvey-Berino J. Minimal in-person support as an adjunct to Internet obesity treatment. Annals of Behavioral Medicine. 2007;33:49-56. [pmid: 17291170].
Michalak L, Trocki K, Katz K. “I am a Muslim and my dad is an alcoholic—what should I do?”: Internet-based advice for Muslims about alcohol. Journal of Muslim Mental Health. 2009;4:47-66. [pmid: 20514354].
Midkiff DM, Wyatt WJ. Ethical issues in the provision of online mental health services (etherapy). Journal of Technology in Human Services. 2008;26:310-332.
Mihalopoulos C, Kiropoulos L, Shih ST, Gunn J, Blashki G, Meadows G. Exploratory economic analyses of two primary care mental health projects: Implications for sustainability. Medical Journal of Australia. 2005;183:S73-S76. [pmid: 16296957].
Miller EA, West DM. Where's the revolution? Digital technology and health care in the Internet age. Journal of Health Politics, Policy and Law. 2009;34:261-284.
Miller ET, Neal DJ, Roberts LJ, Boer JS, Cresskr SO, Metrik J, Marlatt GA. Test-retest reliability of alcohol measures: Is there a difference between Internet-based assessment and traditional methods?. Marlatt GA, Witkewitz K, editors. Addictive behaviors: New readings on etiology, prevention, and treatment. 2009:323-341. Washington, DC. American Psychological Association.
Miller JK, Gergen KJ. Life on the line: The therapeutic potentials of computer-mediated conversation. Journal of Marital and Family Therapy. 1998;24:189-202. [pmid: 9583058].
Miller JL. Mental health on the Web: Therapist, teacher or trouble (counseling online). Counselor. 2001;2:56-63.
Miller TW. Telehealth issues in consulting psychology practice. Consulting Psychology Journal: Practice and Research. 2006;58:82-90.
Miller TW, Kraus RF, Kaak O, Sprang R, Burton D. Telemedicine: A child psychiatry case report. Telemedicine Journal and e-Health. 2002;8:139-141. [pmid: 12020414].
Minden SL, Feinstein A, Kalb RC, Miller D, Mohr DC, Patten SB, Bever C Jr., Narayanaswani P. Evidence-based guideline: Assessment and management of psychiatric disorders in individuals with MS. Neurology. 2014;82(2):174-181. [pmid: 24376275].
Mitchell JE, Agras S, Crow S, Halmi K, Fairburn CG, Bryson S, Kraemer H. Stepped care and cognitive-behavioural therapy for bulimia nervosa: Randomised trial. British Journal of Psychiatry. 2011;198:391-397. [pmid: 21415046].
Mitchell JE, Crosby RD, Wonderlich SA, Crow S, Lancaster K, Simonich H, Myers TC. A randomized trial comparing the efficacy of cognitive-behavioral therapy for bulimia nervosa delivered via telemedicine versus face-to-face. Behaviour Research and Therapy. 2008;46:581-592. [pmid: 18374304].
Mitchell JE, Stanimirovic R, Klein B, Vella-Brodrick D. A randomised controlled trial of a self-guided Internet intervention promoting well-being. Computers in Human Behavior. 2009;25:749-760.
Mitchell KJ, Becker-Blease KA, Finkelhor D. Inventory of problematic Internet experiences encountered in clinical practice. Professional Psychology: Research and Practice. 2005;36:498-509.
Mitchell KJ, Wells M. Problematic Internet experiences: Primary or secondary presenting problems in persons seeking mental health care?. Social Science & Medicine. 2007;65:1136-1141. [pmid: 17566622].
Mittal VA, Tessner KD, Walker EF. Elevated social Internet use and schizotypal personality disorder in adolescents. Schizophrenia Research. 2007;94:50-57. [pmid: 17532188].
Mittman R, Cain M. The future of the Internet in healthcare: A five-year forecast. Hospital Quarterly. 2000;3:63-65. [pmid: 11482271].
Mohr DC. Telemental health: Reflections on how to move the field forward. Clinical Psychology: Science and Practice. 2009;16:343-347.
Mohr DC, Carmody T, Erickson L, Jin L, Leader J. Telephone-administered cognitive behavioral therapy for veterans served by community-based outpatient clinics. Journal of Consulting and Clinical Psychology. 2011;79:261-265. [pmid: 21299274].
Mohr DC, Ho J, Duffecy J, Reifler D, Sokol L, Burns MN, Siddique J. Effect of telephone-administered vs. face-to-face cognitive behavioral therapy on adherence to therapy and depression outcomes among primary care patients: A randomized trial. JAMA. 2012;307:2278-2285. [pmid: 22706833].
Mohr DC, Likosky W, Bertagnolli A, Goodkin DE, Van Der Wende J, Dwyer P, Dick LP. Telephone-administered cognitive-behavioral therapy for the treatment of depressive symptoms in multiple sclerosis. Journal of Consulting and Clinical Psychology. 2000;68:356-361. [pmid: 10780138].
Mohr DC, Siddique J, Ho J, Duffecy J, Jin L, Fokuo JK. Interest in behavioral and psychological treatments delivered face-to-face, by telephone, and by Internet. Annals of Behavioral Medicine. 2010;40:89-98. [pmid: 20652466].
Mohr DC, Vella L, Hart S, Heckman T, Simon G. The effect of telephone–administered psychotherapy on symptoms of depression and attrition: A meta-analysis. Clinical Psychology (New York). 2008;15:243-253.
Molfenter T, Boyle M, Holloway D, Zwick J. Trends in telemedicine use in addiction treatment. Addiction Science & Clinical Practice. 2015;10:14. [pmid: 26016484].
Monaghan S, Wood RT. Internet-based interventions for youth dealing with gambling problems. International Journal of Adolescent Medicine and Health. 2010;22:113-128. [pmid: 20491421].
Moon J, Lee JH. Cue exposure treatment in a virtual environment to reduce nicotine craving: A functional MRI study. CyberPsychology & Behavior. 2009;12:43-45. [pmid: 19025463].
Moore BA, Fazzino T, Garnet B, Cutter CJ, Barry DT. Computer-based interventions for drug use disorders: A systematic review. Journal of Substance Abuse Treatment. 2011;40:215-223. [pmid: 21185683].
Moore MJ, Soderquist J, Werch C. Feasibility and efficacy of a binge drinking prevention intervention for college students delivered via the Internet versus postal mail. Journal of American College Health. 2005;54:38-44. [pmid: 16050327].
Mora L, Nevid J, Chaplin W. Psychologist treatment recommendations for Internet-based therapeutic interventions. Computers in Human Behavior. 2008;24:3052-3062.
Moreno FA, Chong J, Dumbauld J, Humke M, Byreddy S. Use of standard Webcam and Internet equipment for telepsychiatry treatment of depression among underserved Hispanics. Psychiatric Services. 2012;63(12):1213-1217. [pmid: 23026854].
Moreno MA, Vanderstoep A, Parks MR, Zimmerman FJ, Kurth A, Christakis DA. Reducing at-risk adolescents' display of risk behavior on a social networking Web site: A randomized controlled pilot intervention trial. Archives of Pediatrics and Adolescent Medicine. 2009;163:35-41. [pmid: 19124701].
Morgan AJ, Jorm AF. Outcomes of self-help efforts in anxiety disorders. Expert Review of Pharmacoeconomics and Outcomes Research. 2009;9:445-459. [pmid: 19817528].
Morgan AJ, Jorm AF, Mackinnon AJ. Email-based promotion of self-help for subthreshold depression: Mood Memos randomised controlled trial. British Journal of Psychiatry. 2012;200:412-418. [pmid: 22442102].
Morgan RD, Patrick AR, Magaletta PR. Does the use of telemental health alter the treatment experience? Inmates' perceptions of telemental health versus face-to-face treatment modalities. Journal of Consulting and Clinical Psychology. 2008;76:158-162. [pmid: 18229993].
Morie JF. 2009. Re-entry: Online virtual worlds as a healing space for veterans. [Abstract]. Retrieved June 29, 2014 from: http://proceedings.spiedigitallibrary.org/proceeding.aspx?articleid=1334743.
Morie JF, Antonisse J, Bouchard S, Chance E. Virtual worlds as a healing modality for returning soldiers and veterans. Studies in Health Technology and Informatics. 2009;144:273-276. [pmid: 19592780].
Morie JF, Chance E. Extending the reach of health care for obesity and diabetes using virtual worlds. Journal of Diabetes Science and Technology. 2011;5:272-276. [pmid: 21527093].
Moritz S, Jelinek L, Hauschildt M, Naber D. How to treat the untreated: effectiveness of a self-help metacognitive training program (myMCT) for obsessive–compulsive disorder. Dialogues in Clinical Neuroscience. 2010;12:209-220. [pmid: 20623925].
Moritz S, Rufer M. Movement decoupling: A self-help intervention for the treatment of trichotillomania. Journal of Behavior Therapy and Experimental Psychiatry. 2011;42:74-80. [pmid: 20674888].
Moritz S, Schilling L, Hauschildt M, Schroder J, Treszl A. A randomized controlled trial of Internet-based therapy in depression. Behaviour Research and Therapy. 2012;50:513-521. [pmid: 22677231].
Moritz S, Wittekind CE, Hauschildt M, Timpano KR. Do it yourself? Self-help and online therapy for people with obsessive–compulsive disorder. Current Opinion in Psychiatry. 2011;24:541-543. [pmid: 21897252].
Morland LA, Greene CJ, Grubbs K, Kloezeman K, Mackintosh MA, Rosen C, Frueh BC. Therapist adherence to manualized cognitive-behavioral therapy for anger management delivered to veterans with PTSD via videoconferencing. Journal of Clinical Psychology. 2011;67:629-638. [pmid: 21360528].
Morris D, Drake E, Saarimaki A, Bennett C, O'Connor A. Can people find patient decision aids on the Internet?. Patient Education and Counseling. 2008;73:557-560. [pmid: 18789628].
Morris ME, Qusai K, Leen TK, Gorenstein EE, Guilak F, DeLeeuw W. Mobile therapy: Case study evaluations of a cell phone application for emotional self awareness. Journal of Medical Internet Research. 2010;12:e10. [pmid: 20439251].
Moskowitz DA, Melton D, Owczarzak J. PowerON: The use of instant message counseling and the Internet to facilitate HIV/STD education and prevention. Patient Education and Counseling. 2009;77:20-26. [pmid: 19217742].
Moskowitz DS, Young SN. Ecological momentary assessment: What it is and why it is a method of the future in clinical psychopharmacology. Journal of Psychiatry and Neuroscience. 2006;31:13-20. [pmid: 16496031].
Mouthaan J, Sijbrandij M, Reitsma JB, Luitse JSK, Goslings JC, Olff M. Trauma tips: An Internet-based intervention to prevent posttraumatic stress disorder in injured trauma patients. Journal of CyberTherapy and Rehabilitation. 2011;4:331-340.
Moyer M, Haberstroh S, Marbach C. Self-injurious behaviors on the net: A survey of resources for school counselors. Professional School Counseling. 2008;11:277-284.
Mucic D. Transcultural telepsychiatry and its impact on patient satisfaction. Journal of Telemedicine and Telecare. 2010;16:237-242. [pmid: 20423935].
Muller BH, Kull S, Wilhelm FH, Michael T. One-session computer-based exposure treatment for spider-fearful individuals: Efficacy of a minimal self-help intervention in a randomised controlled trial. Journal of Behavior Therapy and Experimental Psychiatry. 2011;42:179-184. [pmid: 21315879].
Muller I, Yardley L. Telephone-delivered cognitive behavioural therapy: A systematic review and meta-analysis. Journal of Telemedicine and Telecare. 2011;17:177-184. [pmid: 21357672].
Mulvaney SA, Rothman RL, Wallston KA, Lybarger C, Dietrich MS. An Internet-based program to improve self-management in adolescents with type 1 diabetes. Diabetes Care. 2010;33:602-604. [pmid: 20032275].
Muñoz RF, Barrera AZ, Delucchi K, Penilla C, Torres LD, Pérez-Stable EJ. International Spanish/English Internet smoking cessation trial yields 20% abstinence rates at 1 year. Nicotine and Tobacco Research. 2009;11:1025-1034. [pmid: 19640833].
Muñoz RF, Lenert LL, Delucchi K, Stoddard J, Perez JE, Penilla C, Pérez-Stable EJ. Toward evidence-based Internet interventions: A Spanish/English Web site for international smoking cessation trials. Nicotine & Tobacco Research. 2006;8:77-87. [pmid: 16497602].
Murdock J, Williams A, Becker K, Bruce MA, Young S. Online versus on-campus: A comparison study of counseling skills courses. Journal of Human Resource and Adult Learning. 2012;8:105-118.
Muresan V, Montgomery GH, David D. Emotional outcomes and mechanisms of change in online cognitive–behavioral interventions: A quantitative meta-analysis of clinical controlled studies. Journal of Technology in Human Services. 2012;30:1-13.
Muroff J, Steketee G, Himle J, Frost R. Delivery of Internet treatment for compulsive hoarding (D.I.T.C.H.). Behaviour Research and Therapy. 2010;48:79-85. [pmid: 19800051].
Murphy L, MacFadden R, Mitchell D. Cybercounseling online: The development of a university-based training program for e-mail counseling. Journal of Technology in Human Services. 2008;26:447-469.
Murphy L, Mitchell D, Hallett R. A comparison of client characteristics in cyber and in-person counseling. Studies in Health Technology and Informatics. 2011;167:149-153. [pmid: 21685658].
Murphy L, Parnass P, Mitchell DL, Hallett R, Cayley P, Seagram S. Client satisfaction and outcome comparisons of online and face-to-face counselling methods. British Journal of Social Work. 2009;39:627-640.
Murphy LJ, Mitchell DL. When writing helps to heal: E-mail as therapy. British Journal of Guidance & Counselling. 1998;26:21-32.
Murray K, Pombo-Carril MG, Bara-Carril N, Grover M, Reid Y, Langham C, Schmidt U. Factors determining uptake of a CD-ROM-based CBT self-help treatment for bulimia: Patient characteristics and subjective appraisals of self-help treatment. European Eating Disorders Review. 2003;11:243-260.
Myers TC, Swan-Kremeier L, Wonderlich S, Lancaster K, Mitchell JE. The use of alternative delivery systems and new technologies in the treatment of patients with eating disorders. International Journal of Eating Disorders. 2004;36:123-143. [pmid: 15282683].
Myin-Germeys I, van Os J, Schwartz JE, Stone AA, Delespaul PA. Emotional reactivity to daily life stress in psychosis. Archives of General Psychiatry. 2001;58:1137-1144. [pmid: 11735842].
Myung SK, McDonnell DD, Kazinets G, Seo HG, Moskowitz JM. Effects of Web- and computer-based smoking cessation programs: Meta-analysis of randomized controlled trials. Archives of Internal Medicine. 2009;169:929-937. [pmid: 19468084].
Nagel DM, Palumbo G. The role of blogging in mental health. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:76-84. Springfield, IL. Charles C. Thomas Publisher.
Najmi S, Amir N. The effect of attention training on a behavioral test of contamination fears in individuals with subclinical obsessive-compulsive symptoms. Journal of Abnormal Psychology. 2010;119:136-142. [pmid: 20141250].
Napolitano MA, Fotheringham M, Tate D, Sciamanna C, Leslie E, Owen N, Marcus B. Evaluation of an Internet-based physical activity intervention: A preliminary investigation. Annals of Behavioral Medicine. 2003;25:92-99. [pmid: 12704010].
National Association of Social Workers. 2012. Social workers and Skype–Part I. Washington, DC. Author.
National Association of Social Workers. 2012. Social workers and Skype–Part II. Washington, DC. Author.
National Association of State Alcohol and Drug Abuse Directors. 2009. Telehealth in state substance use disorder (SUD) services. Washington, DC. Author.
National Board for Certified Counselors & Center for Credentialing and Education. 2009. The practice of Internet counseling. Greensboro, NC. Author.
National Suicide Prevention Lifeline. (n.d.). SuicidePreventionLifeline.org. Retrieved June 29, 2014 from http://www.suicidepreventionlifeline.org.
National Suicide Prevention Lifeline. 2007. Suicide risk assessment standards. Retrieved June 29, 2014 from http://www.suicidepreventionlifeline.org/App_Files/Media/PDF/Training/NSPL%20SRAS%20and%20Prompt%20Questions.pdf.
National Telecommunications and Information Administration. 2010. The Broadband Technology Opportunities Program: Expanding broadband access and adoption in communities across America: Overview of grant awards. Washington, DC. Author.
Naylor MR, Keefe FJ, Brigidi B, Naud S, Helzer JE. Therapeutic interactive voice response for chronic pain reduction and relapse prevention. Pain. 2008;134:335-345. [pmid: 18178011].
Neighbors C, Lee CM, Lewis MA, Fossos N, Walter T. Internet-based personalized feedback to reduce 21st-birthday drinking: A randomized controlled trial of an event-specific prevention intervention. Journal of Consulting and Clinical Psychology. 2009;77:51-63. [pmid: 19170453].
Nelson EL, Barnard M, Cain S. Feasibility of telemedicine intervention for childhood depression. Counselling & Psychotherapy Research. 2006;6:191-195.
Nelson SE, LaPlante DA, Peller AJ, LaBrie RA, Caro G, Shaffer HJ. Implementation of a computerized psychiatric assessment tool at a DUI treatment facility: A case example. Administration and Policy in Mental Health. 2007;34:489-493. [pmid: 17487562].
Nemes S, Rao PA, Zeiler C, Munly K, Holtz KD, Hoffman J. Computerized screening of substance abuse problems in a primary care setting: Older vs. younger adults. American Journal of Drug and Alcohol Abuse. 2004;30:627-642. [pmid: 15540497].
Nesci DA. Multimedia psychodynamic psychotherapy: A preliminary report. Journal of Psychiatric Practice. 2009;15:211-215. [pmid: 19461394].
Neve M, Morgan PJ, Jones PR, Collins CE. Effectiveness of Web-based interventions in achieving weight loss and weight loss maintenance in overweight and obese adults: A systematic review with meta-analysis. Obesity Reviews. 2010;11:306-321. [pmid: 19754633].
Nevonen L, Mark M, Levin B, Lindstrom M, Paulson-Karlsson G. Evaluation of a new Internet-based self-help guide for patients with bulimic symptoms in Sweden. Nordic Journal of Psychiatry. 2006;60:463-468. [pmid: 17162454].
Newman MG. The clinical use of palmtop computers in the treatment of generalized anxiety disorder. Cognitive and Behavioral Practice. 1999;6:222-234.
Newman MG. Technology in psychotherapy: An introduction. Journal of Clinical Psychology. 2004;60:141-145. [pmid: 14724921].
Newman MG, Consoli A, Taylor CB. Computers in assessment and cognitive behavioral treatment of clinical disorders: Anxiety as a case in point. Behavior Therapy. 1997;28:211-235.
Newman MG, Consoli AJ, Taylor CB. A palmtop computer program for the treatment of generalized anxiety disorder. Behavior Modification. 1999;23:597-619. [pmid: 10533442].
Newman MG, Erickson T, Przeworski A, Dzus E. Self-help and minimal–contact therapies for anxiety disorders: Is human contact necessary for therapeutic efficacy?. Journal of Clinical Psychology. 2003;59:251-274. [pmid: 12579544].
Newman MG, Kenardy J, Herman S, Taylor CB. Comparison of palmtop-computer-assisted brief cognitive–behavioral treatment to cognitive–behavioral treatment for panic disorder. Journal of Consulting and Clinical Psychology. 1997;65:178-183. [pmid: 9103747].
Newman MG, Koif DF, Przeworski A, Llera SJ. Anxiety disorders. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:27-44. New York. Routledge/Taylor & Francis Group.
Newman MG, Szkodny LE, Llera SJ, Przeworski A. A review of technology-assisted self-help and minimal contact therapies for drug and alcohol abuse and smoking addiction: Is human contact necessary for therapeutic efficacy?. Clinical Psychology Review. 2011;31:178-186. [pmid: 21095051].
Newnham EA, Doyle EL, Sng AAH, Hooke GR, Page AC. Improving clinical outcomes in psychiatric care with touch-screen technology. Psychological Services. 2012;9:221-223. [pmid: 22662741].
Newton MS, Ciliska D. Internet-based innovations for the prevention of eating disorders: A systematic review. Eating Disorders: The Journal of Treatment & Prevention. 2006;14:365-384.
Newton NC, Andrews G, Teesson M, Vogl LE. Delivering prevention for alcohol and cannabis using the Internet: A cluster randomised controlled trial. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2009;48:579-584.
Newton NC, Teesson M, Vogl LE, Andrews G. Internet-based prevention for alcohol and cannabis use: Final results of the Climate Schools course. Addiction. 2010;105:749-759. [pmid: 20148791].
Nijland N, van Gemert-Pijnen J, Boer H, Steehouder FML, Seydel RE. Evaluation of Internet-based technology for supporting self-care: Problems encountered by patients and caregivers when using self-care applications. Journal of Medical Internet Research. 2008;10:e13. [pmid: 18487137].
Noar SM, Black HG, Pierce LB. Efficacy of computer technology-based HIV prevention interventions: A meta-analysis. AIDS. 2009;23:107-115. [pmid: 19050392].
Norcross JC. Integrating self-help into psychotherapy: 16 practical suggestions. Professional Psychology: Research and Practice. 2006;37:683-693.
Nordgreen T, Havik OE, Ost LG, Furmark T, Carlbring P, Andersson G. Outcome predictors in guided and unguided self-help for social anxiety disorder. Behaviour Research and Therapy. 2012;50:13-21. [pmid: 22134140].
Norman C. CATCH-IT report: Evaluation of an Internet-based smoking cessation program: Lessons learned from a pilot study. Journal of Medical Internet Research. 2004;6:e47. [pmid: 15631971].
Norman CD, Maley O, Li X, Skinner HA. Using the Internet to assist smoking prevention and cessation in schools: A randomized, controlled trial. Health Psychology. 2008;27:799-810. [pmid: 19025276].
Norman S. The use of telemedicine in psychiatry. Journal of Psychiatric and Mental Health Nursing. 2006;13:771-777. [pmid: 17087682].
Norton M, Wonderlich SA, Myers T, Mitchell JE, Crosby RD. The use of palmtop computers in the treatment of bulimia nervosa. European Eating Disorders Review. 2003;11:231-242.
Nundy S, Dick JJ, Chou C-H, Nocon RS, Chin MH, Peek ME. Mobile phone diabetes project led to improved glycemic control and net savings for Chicago plan participants. Health Affairs. 2014;33:265-272. [pmid: 24493770].
Nyman SR, Yardley L. Usability and acceptability of a Website that provides tailored advice on falls prevention activities for older people. Health Informatics Journal. 2009;15:27-39. [pmid: 19218310].
O'Dea B, Campbell A. Healthy connections: Online social networks and their potential for peer support. Studies in Health Technology and Informatics. 2011;168:133-140. [pmid: 21893921].
Oenema A, Brug J, Dijkstra A, de Weerdt I, de Vries H. Efficacy and use of an Internet-delivered computer-tailored lifestyle intervention, targeting saturated fat intake, physical activity and smoking cessation: A randomized controlled trial. Annals of Behavioral Medicine. 2008;35:125-135. [pmid: 18363076].
Oenema A, Tan F, Brug J. Short-term efficacy of a Web-based computer-tailored nutrition intervention: Main effects and mediators. Annals of Behavioral Medicine. 2005;29:54-63. [pmid: 15677301].
Office of National Drug Control Policy. 2010. National drug control strategy: 2010. Washington, DC. Author.
Oh H, Rizo C, Enkin M, Jadad A. What is eHealth (3): A systematic review of published definitions. Journal of Medical Internet Research. 2005;7:e1. [pmid: 15829471].
O'Kearney R, Gibson M, Christensen H, Griffiths KM. Effects of a cognitive–behavioural Internet program on depression, vulnerability to depression and stigma in adolescent males: A school-based controlled trial. Cognitive Behaviour Therapy. 2006;35:43-54. [pmid: 16500776].
O'Kearney R, Kang K, Christensen H, Griffiths K. A controlled trial of a school-based Internet program for reducing depressive symptoms in adolescent girls. Depression and Anxiety. 2009;26:65-72. [pmid: 18828141].
O'Kearney R, Kang K, Gibson M, Christensen H, Griffiths K. A CBT Internet program for depression in adolescents (MoodGYM): Effects on depressive symptoms, attributional style, self-esteem and beliefs about depression. Einstein D, editor. Innovations and advances in cognitive behaviour therapy. 2007:197-204. Bowen Hills, QLD, Australia. Australian Academic Press.
Olmstead TA, Ostrow CD, Carroll KM. Cost-effectiveness of computer-assisted training in cognitive–behavioral therapy as an adjunct to standard care for addiction. Drug and Alcohol Dependence. 2010;110(3):200-207. [pmid: 20392575].
Olson MM, Russell CS, White MB. Technological implications for clinical supervision and practice. The Clinical Supervisor. 2001;20:201-215.
Olsson EMG, El Alaoui S, Carlberg B, Carlbring P, Ghaderi A. Internet-based biofeedback-assisted relaxation training in the treatment of hypertension: A pilot study. Applied Psychophysiology and Biofeedback. 2010;35:163-170. [pmid: 19949851].
Ondersma SJ, Chase SK, Svikis DS, Schuster CR. Computer-based brief motivational intervention for perinatal drug use. Journal of Substance Abuse Treatment. 2005;28:305-312. [pmid: 15925264].
Ondersma SJ, Grekin ER, Svikis D. The potential for technology in brief interventions for substance use, and during-session prediction of computer-delivered brief intervention response. Substance Use & Misuse. 2011;46:77-86. [pmid: 21190408].
Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention a randomized trial with postpartum women. American Journal of Preventive Medicine. 2007;32:231-238. [pmid: 17236741].
Ookita SY, Tokuda H. A virtual therapeutic environment with user projective agents. CyberPsychology & Behavior. 2001;4:155-167. [pmid: 11709904].
Optale G, Pastore M, Marin S, Bordin D, Nasta A, Pianon C. Male sexual dysfunctions: Immersive virtual reality and multimedia therapy. Riva G, Botella C, Legeron P, Optale G, editors. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:165-180. Amsterdam. Ios Press.
Oravec JA. Internet and computer technology hazards: Perspectives for family counselling. British Journal of Guidance & Counselling. 2000;28:309-324.
Oravec JA. Online counselling and the Internet: Perspectives for mental health care supervision and education. Journal of Mental Health. 2000;9:121-135.
Orbach G, Lindsay S, Grey S. A randomised placebo-controlled trial of a self-help Internet-based intervention for test anxiety. Behaviour Research and Therapy. 2007;45:483-496. [pmid: 16814744].
O'Reilly R, Bishop J, Maddox K, Hutchinson L, Fisman M, Takhar J. Is telepsychiatry equivalent to face-to-face psychiatry? Results from a randomized controlled equivalence trial. Psychiatric Services. 2007;58:836-843. [pmid: 17535945].
Ormrod JA, Kennedy L, Scott J, Cavanagh K. Computerised cognitive behavioural therapy in an adult mental health service: A pilot study of outcomes and alliance. Cognitive Behaviour Therapy. 2010;39:188-192. [pmid: 20485996].
Orr PP. Distance supervision: Research, findings, and considerations for art therapy. The Arts in Psychotherapy. 2010;37:106-111.
Orwat C, Graefe A, Faulwasser T. Towards pervasive computing in health care–A literature review. BMC Medical Informatics and Decision Making. 2008;8. 26.
Orzack MH, Ross CJ. Should virtual sex be treated like other sex addictions?. Sexual Addiction & Compulsivity. 2000;7:113-125.
Orzack MH, Voluse AC, Wolf D, Hennen J. An ongoing study of group treatment for men involved in problematic Internet-enabled sexual behavior. CyberPsychology & Behavior. 2006;9:348-360. [pmid: 16780403].
Ota A, Takahashi Y. Factors associated with successful smoking cessation among participants in a smoking cessation program involving use of the Internet, e-mails, and mailing-list. Japanese Journal of Public Health. 2005;52:999-1005. [pmid: 16408486].
Ottenstein RJ. Supporting remote and complicated critical incidents through e-mail support teams. International Journal of Emergency Mental Health. 2002;4:213-216. [pmid: 12387194].
Ouellette PM, Sells S. Creating a telelearning community for training social work practitioners working with troubled youth and their families. Journal of Technology in Human Services. 2001;18:101-116.
Owen JE, Klapow JC, Roth DL, Shuster JL Jr., Bellis J, Meredith R, Tucker DC. Randomized pilot of a self-guided Internet coping group for women with early-stage breast cancer. Annals of Behavioral Medicine. 2005;30:54-64. [pmid: 16097906].
Pahwa B. 2005. Evaluation of an online substance abuse prevention exercise. Arlington, TX. University of Texas at Arlington.
Pahwa B, Schoech D. Issues in the evaluation of an online prevention exercise. Journal of Technology in Human Services. 2008;26:259-281.
Pak R, Price MM, Thatcher J. Age-sensitive design of online health information: Comparative usability study. Journal of Medical Internet Research. 2009;11:e45. [pmid: 19917549].
Palermo TM, Wilson AC, Peters M, Lewandowski A, Somhegyi H. Randomized controlled trial of an Internet-delivered family cognitive–behavioral therapy intervention for children and adolescents with chronic pain. Pain. 2009;146:205-213. [pmid: 19695776].
Palmer NB, Myers KM, Vander SA, McCarty CA, Geyer JR, Desalvo A. Attention-deficit/hyperactivity disorder and telemental health. Current Psychiatry Reports. 2010;12:409-417. [pmid: 20625857].
Palmiter D Jr., Renjilian D. Clinical Web pages: Do they meet expectations?. Professional Psychology: Research and Practice. 2003;34:164-169.
Palmqvist B, Carlbring P, Andersson G. Internet-delivered treatments with or without therapist input: Does the therapist factor have implications for efficacy and cost?. Expert Review of Pharmacoeconomics and Outcomes Research. 2007;7:291-297. [pmid: 20528315].
Panzarella C, Wasserman AL, Barnett BE, Witte G. Internet adventures in doctoral education in clinical psychology. Behavior Therapist. 1999;22:45-67.
Park A, Nitzke S, Kritsch K, Kattelmann K, White A, Boeckner L, Zhang Z. Internet-based interventions have potential to affect short-term mediators and indicators of dietary behavior of young adults. Journal of Nutrition Education and Behavior. 2008;40:288-297. [pmid: 18725147].
Parker G, Fletcher K, Barrett M, Synnott H, Breakspear M, Hyett M, Hadzi-Pavlovic D. Screening for bipolar disorder: The utility and comparative properties of the MSS and MDQ measures. Journal of Affective Disorders. 2008;109:83-89. [pmid: 18082895].
Parks KA, Pardi AM, Bradizza CM. Collecting data on alcohol use and alcohol-related victimization: A comparison of telephone and Web-based survey methods. Journal of Studies on Alcohol. 2006;67:318-323. [pmid: 16562415].
Paschall MJ, Antin T, Ringwalt CL, Saltz RF. Evaluation of an Internet-based alcohol misuse prevention course for college freshmen: Findings of a randomized multi-campus trial. American Journal of Preventive Medicine. 2011;41:300-308. [pmid: 21855745].
Paschall MJ, Bersamin M, Fearnow-Kenney M, Wyrick D, Currey D. Short-term evaluation of a Web-based college alcohol misuse and harm prevention course (College Alc). Journal of Alcohol and Drug Education. 2006;50:49-65.
Passetti LL, Godley SH, Scott CK, Siekmann M. A low-cost follow-up resource: Using the World Wide Web to maximize client location efforts. American Journal of Evaluation. 2000;21:195-203.
Patrick K, Raab F, Adams AM, Dillon L, Zabinski M, Rock LC, Norman GJ. A text message-based intervention for weight loss: Randomized controlled trial. Journal of Medical Internet Research. 2009;11:e1. [pmid: 19141433].
Patten CA, Croghan IT, Meis TM, Decker PA, Pingree S, Colligan RC, Gustafson DH. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Education and Counseling. 2006;64:249-258. [pmid: 16616449].
Patten CA, Rock E, Meis TM, Decker PA, Colligan RC, Pingree S, Gustafson DH. Frequency and type of use of a home-based, Internet intervention for adolescent smoking cessation. Journal of Adolescent Health. 2007;41:437-443. [pmid: 17950163].
Patten SB. Prevention of depressive symptoms through the use of distance technologies. Psychiatric Services. 2003;54:396-398. [pmid: 12610251].
Pawsey B, Castle DJ. Web watch: Treatment sites for consumers–”e-health”. Dual Diagnosis. 2005;2:89-91.
Paxton SJ, Franko DL. Body image and eating disorders. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:151-168. New York. Routledge/Taylor & Francis Group.
Paxton SJ, McLean SA, Gollings EK, Faulkner C, Wertheim EH. Comparison of face-to-face and Internet interventions for body image and eating problems in adult women: An RCT. International Journal of Eating Disorders. 2007;40:692-704. [pmid: 17702020].
Pealer LN, Weiler RM, Pigg RM Jr., Miller D, Dorman SM. The feasibility of a Web-based surveillance system to collect health risk behavior data from college students. Health Education & Behavior. 2001;29:547-559. [pmid: 11575685].
Peck DF. The therapist–client relationship, computerized self-help and active therapy ingredients. Clinical Psychology & Psychotherapy. 2010;17:147-153. [pmid: 19946947].
Pederson LL, Blumenthal DS, Dever A, McGrady G. A Web-based smoking cessation and prevention curriculum for medical students: Why, how, what, and what next. Drug and Alcohol Review. 2006;25:39-47. [pmid: 16492576].
Pedrero-Perez EJ, Rojo-Mota G, Ruiz-Sanchez de Leon JM, Llanero-Luque M, Puerta-Garcia C. Rehabilitación cognitiva en el tratamiento de las adicciones. Cognitive remediation in addictions treatment. Revista de Neurologia. 2011;52:163-172. [pmid: 21287493].
Peng BW, Schoech D. Grounding online prevention interventions in theory: Guidelines from a review of selected theories and research. Journal of Technology in Human Services. 2008;26:376-396.
Pentland AS. Healthwear: Medical technology becomes wearable. Studies in Health Technology and Informatics. 2004;118:55-65. [pmid: 16301769].
Pereira J, Bruera E, Macmillan K, Kavanagh S. Palliative cancer patients and their families on the Internet: Motivation and impact. Journal of Palliative Care. 2000;16:13-19. [pmid: 11965929].
Perini S, Titov N, Andrews G. Clinician-assisted Internet-based treatment is effective for depression: Randomized controlled trial. Australian and New Zealand Journal of Psychiatry. 2009;43:571-578. [pmid: 19440890].
Perpiñá C, Botella C, Baños RM. Virtual reality in eating disorders. European Eating Disorders Review. 2003;11:261-278.
Pestello FG, Davis-Berman J. Taking anti-depressant medication: A qualitative examination of Internet postings. Journal of Mental Health. 2008;17:349-360.
Peterson MR, Beck RL. E-mail as an adjunctive tool in psychotherapy: Response and responsibility. American Journal of Psychotherapy. 2003;57:167-181. [pmid: 12817548].
Pew Internet and American Life Project. 2006. Online health search 2006. Washington, DC. Pew Research Center.
Pew Research Center. 2012. Internet adoption trend data: Adults. Washington, DC. Author.
Pew Research Center. 2013. Health online 2013. Washington DC. Author.
Pew Research Center. 2014. The Web at 25 in the US. Washington DC. Author.
Pew Research Center. 2015. US smartphone use in 2015. Washington DC. Author.
Piasecki TM, Hufford MR, Solhan M, Trull TJ. Assessing clients in their natural environments with electronic diaries: Rationale, benefits, limitations, and barriers. Psychological Assessment. 2007;19:25-43. [pmid: 17371121].
Pier C, Austin DW, Klein B, Mitchell J, Schattner P, Ciechomski L, Wade V. A controlled trial of Internet-based cognitive–behavioural therapy for panic disorder with face-to-face support from a general practitioner or email support from a psychologist. Mental Health in Family Medicine. 2008;5:29-39. [pmid: 22477844].
Pierce LL, Steiner VL, Khuder SA, Govoni AL, Horn LJ. The effect of a Web-based stroke intervention on carers' well-being and survivors' use of healthcare services. Disability and Rehabilitation. 2009;31:1676-1684. [pmid: 19479528].
Pies R. The Internet “expert”: Promise and perils. Hsiung RC, editor. E-therapy: Case studies, guiding principles, and the clinical potential of the Internet. 2002:24-38. New York. W. W. Norton & Co.
Pietrzak RH, Olver J, Norman T, Piskulic D, Maruff P, Snyder PJ. A comparison of the CogState Schizophrenia Battery and the Measurement and Treatment Research to Improve Cognition in Schizophrenia (MATRICS) Battery in assessing cognitive impairment in chronic schizophrenia. Journal of Clinical and Experimental Neuropsychology. 2009;31:848-859. [pmid: 19142774].
Piette JD, Richardson C, Himle J, Duffy S, Torres T, Vogel M, Valenstein M. A randomized trial of telephonic counseling plus walking for depressed diabetes patients. Medical Care. 2011;49:641-648. [pmid: 21478777].
Pike KJ, Rabius V, McAlister A, Geiger A. American Cancer Society's QuitLink: Randomized trial of Internet assistance. Nicotine & Tobacco Research. 2007;9:415-420. [pmid: 17365773].
Pisinger C, Jorgensen MM, Moller NE, Dossing M, Jorgensen T. A cluster randomized trial in general practice with referral to a group-based or an Internet-based smoking cessation programme. Journal of Public Health. 2010;32:62-70. [pmid: 19617300].
Pitkänen A, Välimäki M, Kuosmanen L, Katajisto J, Koivunen M, Hätönen H, Knapp M. Patient education methods to support quality of life and functional ability among patients with schizophrenia: A randomised clinical trial. Quality of Life Research. 2012;21:247-256. [pmid: 21655934].
Pitts V. Illness and Internet empowerment: Writing and reading breast cancer in cyberspace. Health (London). 2004;8:33-59. [pmid: 15018717].
Pletneva N, Cruchet S, Simonet MA, Kajiwara M, Boyer C. Results of the 10 HON survey on health and medical Internet use. Studies in Health Technology and Informatics. 2011;169:73-77. [pmid: 21893717].
Pohjanoksa-Mäntylä M, Saari JK, Närhi U, Karjalainen A, Pylkkänen K, Airaksinen MS, Bell JS. How and why do people with depression access and utilize online drug information: A qualitative study. Journal of Affective Disorders. 2009;114:333-339. [pmid: 18691765].
Pollard RQ, Dean RK, O'Hearn A, Haynes SL. Adapting health education material for Deaf audiences. Rehabilitation Psychology. 2009;54:232-238. [pmid: 19469615].
Pollock SL. Internet counseling and its feasibility for marriage and family counseling. Family Journal. 2006;14:65-70.
Polomano RC, Droog N, Purinton MC, Cohen AS. Social support Web-based resources for patients with chronic pain. Journal of Pain and Palliative Care Pharmacotherapy. 2007;21:49-55. [pmid: 18032357].
Polosa R, Russo C, Di Maria A, Arcidiacono G, Morjaria JB, Piccillo GA. Feasibility of using e-mail counseling as part of a smoking-cessation program. Respiratory Care. 2009;54:1033-1039. [pmid: 19650944].
Polyakov A, Palmer E, Devitt PG, Coventry BJ. Clinicians and computers: Friends or foes?. Teaching and Learning in Medicine. 2000;12:91-95. [pmid: 11228684].
Polzien KM, Jakicic JM, Tate DF, Otto AD. The efficacy of a technology-based system in a short-term behavioral weight loss intervention. Obesity (Silver Spring). 2007;15:825-830. [pmid: 17426316].
Pomerantz JM. Clinical responsibility and e-therapy. Drug Benefit Trends. 2002;14:29-30.
Portnoy DB, Scott-Sheldon LAJ, Johnson BT, Carey MP. Computer-delivered interventions for health promotion and behavioral risk reduction: A meta-analysis of 75 randomized controlled trials, 1988–2007. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2008;47:3-16.
Possemato K, Ouimette P, Geller PA. Internet-based expressive writing for kidney transplant recipients: Effects on posttraumatic stress and quality of life. Traumatology. 2010;16:49-54.
Possemato K, Ouimette P, Knowlton P. A brief self-guided telehealth intervention for post-traumatic stress disorder in combat veterans: A pilot study. Journal of Telemedicine and Telecare. 2011;17:245-250. [pmid: 21636687].
Postel MG, De Haan HA, De Jong CAJ. E-therapy for mental health problems: A systematic review. Telemedicine and e-Health. 2008;14:707-714. [pmid: 18817501].
Postel MG, De Haan HA, De Jong CAJ. Evaluation of an e-therapy program for problem drinkers: A pilot study. Substance Use & Misuse. 2010;45:2059-2075. [pmid: 20438314].
Postel MG, De Haan HA, Ter Huurne ED, Becker ES, De Jong CA. Characteristics of problem drinkers in e-therapy versus face-to-face treatment. American Journal of Drug and Alcohol Abuse. 2011;37:537-542. [pmid: 21797813].
Postel MG, De Jong CA, De Haan HA. Does e-therapy for problem drinking reach hidden populations?. American Journal of Psychiatry. 2005;162:2393. [pmid: 16330613].
Powell DJ. Maximizing the benefits of online therapy. Addiction Professional. 2006;4:29-33.
Presti G, Moderato P, Gentile R. Improving the quality of our life in the digital society: Where psychology might help, and what psychologists might do. Cognitive Processing. 2003;4. 29.
Pretorius N, Arcelus J, Beecham J, Dawson H, Doherty F, Eisler I, Schmidt U. Cognitive-behavioural therapy for adolescents with bulimic symptomatology: The acceptability and effectiveness of Internet-based delivery. Behaviour Research and Therapy. 2009;47:729-736. [pmid: 19515360].
Price J, Sapci H. Law & psychiatry: Telecourt: The use of videoconferencing for involuntary commitment hearings in academic health centers. Psychiatric Services. 2007;58:17-18. [pmid: 17215408].
Proudfoot J. Computer-based treatment for anxiety and depression: Is it feasible? Is it effective?. Neuroscience and Biobehavioral Reviews. 2004;28:353-363. [pmid: 15225977].
Proudfoot J, Parker G, Benoit M, Manicavasagar V, Smith M. Helping patients adjust to the diagnosis of bipolar disorder: The role of an online psychoeducation program. Australian and New Zealand Journal of Psychiatry. 2010;41:A498.
Proudfoot J, Parker G, Hyett M, Manicavasagar V, Smith M, Grdovic S, Greenfield L. Next generation of self-management education: Web-based bipolar disorder program. Australian and New Zealand Journal of Psychiatry. 2007;41:903-909. [pmid: 17924243].
Proudfoot J, Ryden C, Everitt B, Shapiro DA, Goldberg D, Mann A, Gray JA. Clinical efficacy of computerised cognitive–behavioural therapy for anxiety and depression in primary care: Randomised controlled trial. British Journal of Psychiatry. 2004;185:46-54. [pmid: 15231555].
Przeworski A, Newman MG. Palmtop computer-assisted group therapy for social phobia. Journal of Clinical Psychology. 2004;60:179-188. [pmid: 14724925].
Przeworski A, Newman MG. Efficacy and utility of computer-assisted cognitive behavioural therapy for anxiety disorders. Clinical Psychologist. 2006;10:43-53.
Pull CB. Self-help Internet interventions for mental disorders. Current Opinion in Psychiatry. 2006;19:50-53. [pmid: 16612179].
Purves DG, Bennett M, Wellman N. An open trial in the NHS of Blues Begone: A new home based computerized CBT program. Behavioural and Cognitive Psychotherapy. 2009;37:541-551. [pmid: 19703330].
Puskar K, Schlenk EA, Callan J, Bickmore T, Sereika S. Relational agents as an adjunct in schizophrenia treatment. Journal of Psychosocial Nursing and Mental Health Services. 2011;49:22-29. [pmid: 21766736].
Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: Change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technology & Therapeutics. 2008;10:160-168. [pmid: 18473689].
Rabinowitz T, Murphy KM, Amour JL, Ricci MA, Caputo MP, Newhouse PA. Benefits of a telepsychiatry consultation service for rural nursing home residents. Telemedicine Journal and e-Health. 2010;16:34-40. [pmid: 20070161].
Rabius V, McAlister AL, Geiger A, Huang P, Todd R. Telephone counseling increases cessation rates among young adult smokers. Health Psychology. 2004;23:539-541. [pmid: 15367074].
Rabius V, Pike JK, Wiatrek D, McAlister LA. Comparing Internet assistance for smoking cessation: 13-month follow-up of a six-arm randomized controlled trial. Journal of Medical Internet Research. 2008;10:e45. [pmid: 19033146].
Racine AD, Alderman EM, Avner JR. Effect of telephone calls from primary care practices on follow-up visits after pediatric emergency department visits: Evidence from the Pediatric Emergency Department Links to Primary Care (PEDLPC) randomized controlled trial. Archives of Pediatrics and Adolescent Medicine. 2009;163:505-511. [pmid: 19487605].
Raento M, Oulasvirta A, Eagle N. Smartphones: An emerging tool for social scientists. Sociological Methods and Research. 2009;37:426-454.
Ragusea AS. The more things change, the more they stay the same: Ethical issues in the provision of telehealth. Knapp SJ, Gottlieb MC, Handelsman MM, VandeCreek LD, editors. APA handbook of ethics in psychology: Vol 2. Practice, teaching, and research. 2012:183-198. Washington, DC. American Psychological Association.
Ragusea AS, VandeCreek L. Suggestions for the ethical practice of online psychotherapy. Psychotherapy: Theory, Research, Practice, Training. 2003;40:94-102.
Rahman A, Nizami A, Minhas A, Niazi R, Slatch M, Minhas F. E-mental health in Pakistan: A pilot study of training and supervision in child psychiatry using the Internet. Psychiatric Bulletin. 2006;30:149-152.
Ramo DE, Hall SM, Prochaska JJ. Reaching young adult smokers through the Internet: Comparison of three recruitment mechanisms. Nicotine and Tobacco Research. 2010;12:768-775. [pmid: 20530194].
Ramos-Ríos R, Mateos R, Lojo D, Conn DK, Patterson T. Telepsychogeriatrics: A new horizon in the care of mental health problems in the elderly. International Psychogeriatrics. 2012;24:1708-1724. [pmid: 22687259].
Rasmussen SR. The cost-effectiveness of telephone counselling to aid smoking cessation in Denmark: A modelling study. Scandinavian Journal of Public Health. 2012;41(1):4-10. [pmid: 23160318].
Rassau A, Arco L. Effects of chat-based on-line cognitive behavior therapy on study related behavior and anxiety. Behavioural and Cognitive Psychotherapy. 2003;31:377-381.
Rasu RS, Hunter CM, Peterson AL, Maruska HM, Foreyt JP. Economic evaluation of an Internet-based weight management program. American Journal of Managed Care. 2010;16:e98-104. [pmid: 20370312].
Raths D. Recovery support for the Facebook generation. Addiction Professional. 2009;7:48-49.
Read J. Schizophrenia, drug companies and the Internet. Social Science & Medicine. 2008;66:99-109. [pmid: 17826878].
Reavley NJ, Jorm AF. The quality of mental disorder information Websites: A review. Patient Education and Counseling. 2011;85:e16-e25. [pmid: 21087837].
Recupero PR. Legal concerns for psychiatrists who maintain Web sites. Psychiatric Services. 2006;57:450-452. [pmid: 16603737].
Recupero PR. Ethics of medical records and professional communications. Child and Adolescent Psychiatric Clinics of North America. 2008;17:37-51. viii. [pmid: 18036478].
Recupero PR. The mental status examination in the age of the Internet. Journal of the American Academy of Psychiatry and the Law. 2010;38:15-26. [pmid: 20305070].
Recupero PR, Harms S. Using email to conduct a therapeutic relationship. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:3-14. Springfield, IL. Charles C. Thomas Publisher.
Recupero P, Rainey SE. Forensic aspects of e-therapy. Journal of Psychiatric Practice. 2005;11:405-410. [pmid: 16304510].
Recupero PR, Rainey SE. Informed consent to e-therapy. American Journal of Psychotherapy. 2005;59:319-331. [pmid: 16555461].
Recupero PR, Rainey SE. Characteristics of e-therapy Web sites. Journal of Clinical Psychiatry. 2006;67:1435-1440. [pmid: 17017831].
Rees CS, Stone S. Therapeutic alliance in face-to-face versus videoconferenced psychotherapy. Professional Psychology: Research and Practice. 2005;36:649-653.
Rees T. Web site helps families cope with childhood illnesses. Children's Hospital of Philadelphia undergoes Internet expansion. Profiles in Healthcare Marketing. 2002;18:37-41. 3. [pmid: 11915204].
Reese HE, McNally RJ, Najmi S, Amir N. Attention training for reducing spider fear in spider-fearful individuals. Journal of Anxiety Disorders. 2010;24:657-662. [pmid: 20510577].
Reese RJ, Conoley CW, Brossart DF. Effectiveness of telephone counseling: A field-based investigation. Journal of Counseling Psychology. 2002;49:233-242.
Reese RJ, Conoley CW, Brossart DF. The attractiveness of telephone counseling: An empirical investigation of client perceptions. Journal of Counseling & Development. 2006;84:54-60.
Reeves T. A controlled study of assisted bibliotherapy: An assisted self-help treatment for mild to moderate stress and anxiety. Journal of Psychiatric and Mental Health Nursing. 2010;17:184-190. [pmid: 20465765].
Regan S, Reyen M, Lockhart AC, Richards AE, Rigotti NA. An interactive voice response system to continue a hospital-based smoking cessation intervention after discharge. Nicotine and Tobacco Research. 2011;13:255-260. [pmid: 21330278].
Reger GM, Holloway KM, Candy C, Rothbaum BO, Difede J, Rizzo AA, Gahm GA. Effectiveness of virtual reality exposure therapy for active duty soldiers in a military mental health clinic. Journal of Traumatic Stress. 2011;24:93-96. [pmid: 21294166].
Reger MA, Gahm GA. A meta-analysis of the effects of Internet- and computer-based cognitive-behavioral treatments for anxiety. Journal of Clinical Psychology. 2009;65:53-75. [pmid: 19051274].
Reis J, McGinty B, Jones S. An e-learning caregiving program for prostate cancer patients and family members. Journal of Medical Systems. 2003;27:1-12. [pmid: 12617194].
Revere D, Dunbar PJ. Review of computer-generated outpatient health behavior interventions: Clinical encounters “in absentia”. Journal of the American Medical Informatics Association. 2001;8:62-79. [pmid: 11141513].
Rey B, Alcaniz M, Lozano JA. New technologies for providing remote psychological treatments. Studies in Health Technology and Informatics. 2004;99:181-197. [pmid: 15295151].
Reynolds B, Dallery J, Shroff P, Patak M, Leraas K. A Web-based contingency management program with adolescent smokers. Journal of Applied Behavior Analysis. 2008;41:597-601. [pmid: 19192862].
Reynolds DJ Jr., Stiles WB. Online data collection for psychotherapy process research. CyberPsychology and Behavior. 2007;10:92-99. [pmid: 17305454].
Reynolds DJ Jr., Stiles WB, Grohol JM. An investigation of session impact and alliance in Internet based psychotherapy: Preliminary results. Counselling & Psychotherapy Research. 2006;6:164-168.
Rhodes SD, Hergenrather KC, Duncan J, Vissman AT, Miller C, Wilkin AM, Eng E. A pilot intervention utilizing Internet chat rooms to prevent HIV risk behaviors among men who have sex with men. Public Health Reports. 2010;125(Suppl 1):29-37. [pmid: 20408385].
Ribisl KM. The potential of the Internet as a medium to encourage and discourage youth tobacco use. Tobacco Control. 2003;12:I48-I59. [pmid: 12773785].
Rice E, Lee A, Taitt S. Cell phone use among homeless youth: Potential for new health interventions and research. Journal of Urban Health. 2011;88:1175-1182. [pmid: 22076445].
Richard MA. Cyberspace: Issues and challenges for EAP providers. Employee Assistance Quarterly. 2003;19:51-60.
Richards D. Features and benefits of online counselling: Trinity College online mental health community. British Journal of Guidance & Counselling. 2009;37:231-242.
Richards JC, Klein B, Austin DW. Internet cognitive behavioural therapy for panic disorder: Does the inclusion of stress management information improve end-state functioning?. Clinical Psychologist. 2006;10:2-15.
Richardson LK, Frueh BC, Grubaugh AL, Egede L, Elhai JD. Current directions in videoconferencing tele-mental health research. Clinical Psychology: Science and Practice. 2009;16:323-338. [pmid: 20161010].
Rideout VJ, Foehr UG, Roberts DF. 2010. Generation M2 media in the lives of 8- to 18- year olds: A Kaiser Family Foundation study. Menlo Park, CA. The Henry J. Kaiser Family Foundation.
Riley W, Obermayer J, Jean-Mary J. Internet and mobile phone text messaging intervention for college smokers. Journal of American College Health. 2008;57:245-248. [pmid: 18809542].
Riley WT, Schumann MF, Forman-Hoffman VL, Mihm P, Applegate BW, Asif O. Responses of practicing psychologists to a Web site developed to promote empirically supported treatments. Professional Psychology: Research and Practice. 2007;38:44-53.
Rimoldi G, Lewis P, Jampala C. 2012. Help at the hip: Increasing resiliency in high risk suicidal veterans through interactive text messaging. New York. Veterans Health Administration.
Riper H, Kramer J, Conijn B, Smit F, Schippers G, Cuijpers P. Translating effective Web-based self-help for problem drinking into the real world. Alcoholism: Clinical and Experimental Research. 2009;33:1401-1408.
Riper H, Kramer J, Keuken M, Smit F, Schippers G, Cuijpers P. Predicting successful treatment outcome of Web-based self-help for problem drinkers: Secondary analysis from a randomized controlled trial. Journal of Medical Internet Research. 2008;10:e46. [pmid: 19033150].
Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: A pragmatic randomized trial. Addiction. 2008;103:218-227. [pmid: 18199300].
Risk A, Petersen C. Health information on the Internet: Quality issues and international initiatives. Journal of the American Medical Association. 2002;287:2713-2715. [pmid: 12020308].
Ritterband LM, Borowitz S, Cox DJ, Kovatchev B, Walker LS, Lucas V, Sutphin JL. Using the Internet to provide information prescriptions. Pediatrics. 2005;116:e643-e647. [pmid: 16263978].
Ritterband LM, Cox DJ, Gordon TL, Borowitz SM, Kovatchev BP, Walker LS, Sutphin JL. Examining the added value of audio, graphics, and interactivity in an Internet intervention for pediatric encopresis. Children's Health Care. 2006;35:47-59.
Ritterband LM, Cox DJ, Walker LS, Kovatchev B, McKnight L, Patel K, Sutphin JL. An Internet intervention as adjunctive therapy for pediatric encopresis. Journal of Consulting and Clinical Psychology. 2003;71:910-917. [pmid: 14516239].
Ritterband LM, Gonder-Frederick LA, Cox DJ, Clifton AD, West RW, Borowitz SM. Internet interventions: In review, in use, and into the future. Professional Psychology: Research and Practice. 2003;34:527-534.
Ritterband LM, Palermo TM. Introduction to the special issue: eHealth in pediatric psychology. Journal of Pediatric Psychology. 2009;34:453-456. [pmid: 19264878].
Ritterband LM, Tate DF. The science of Internet interventions. Introduction. Annals of Behavioral Medicine. 2009;38:1-3. [pmid: 19816750].
Ritterband LM, Thorndike FP, Cox DJ, Kovatchev BP, Gonder-Frederick LA. A behavior change model for Internet interventions. Annals of Behavioral Medicine. 2009;38:18-27. [pmid: 19802647].
Ritterband LM, Thorndike FP, Gonder-Frederick LA, Magee JC, Bailey ET, Saylor DK, Morin CM. Efficacy of an Internet-based behavioral intervention for adults with insomnia. Archives of General Psychiatry. 2009;66:692-698. [pmid: 19581560].
Ritterband LM, Thorndike F, Vasquez D, Saylor D. Treatment credibility and satisfaction with Internet interventions. Bennett-Levy J, Richards DA, Farrand P, Christensen H, Griffiths KM, Kavanaugh DJ, Williams C, editors. Oxford guide to low intensity CBT interventions. 2010:235-240. New York. Oxford University Press.
Riva G. Virtual environments in clinical psychology. Psychotherapy: Theory, Research, Practice, Training. 2003;40:68-76.
Riva G. 2004. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. Amsterdam. Ios Press.
Riva G, Bacchetta M, Cesa G, Conti S, Molinari E. The use of VR in the treatment of eating disorders. Riva G, Botella C, Legeron P, Optale G, editors. Cybertherapy: Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:121-164. Amsterdam. Ios Press.
Riva G, Baños RM, Botella C, Wiederhold BK, Gaggioli A. Positive technology: Using interactive technologies to promote positive functioning. Cyberpsychology, Behavior, and Social Networking. 2012;15:69-77.
Riva G, Gaggioli A, Villani D, Preziosa A, Morganti F, Corsi R, Vezzadini L. NeuroVR: An open source virtual reality platform for clinical psychology and behavioral neurosciences. Studies in Health Technology and Informatics. 2007;125:394-399. [pmid: 17377310].
Rizvi SL, Dimeff LA, Skutch J, Carroll D, Linehan MM. A pilot study of the DBT coach: An interactive mobile phone application for individuals with borderline personality disorder and substance use disorder. Behavior Therapy. 2011;42:589-600. [pmid: 22035988].
Rizzo AS, Difede J, Rothbaum BO, Reger G, Spitalnick J, Cukor J, McLay R. Development and early evaluation of the Virtual Iraq/Afghanistan exposure therapy system for combat-related PTSD. Annals of the New York Academy of Sciences. 2010;1208:114-125. [pmid: 20955333].
Rizzo A, Rothbaum BO, Graap K. Virtual reality applications for the treatment of combat-related PTSD. Figley CR, Nash WP, editors. Combat stress injury: Theory, research, and management. 2007:183-204. New York. Routledge/Taylor & FrancisGroup.
Robertson L, Smith M, Castle D, Tannenbaum D. Using the Internet to enhance the treatment of depression. Australasian Psychiatry. 2006;14:413-417. [pmid: 17116083].
Robinson E, Titov N, Andrews G, McIntyre K, Schwencke G, Solley K. Internet treatment for generalized anxiety disorder: A randomized controlled trial comparing clinician vs. technician assistance. PLOS ONE. 2010;5:e10942. [pmid: 20532167].
Robinson P, Serfaty M. The use of e-mail in the identification of bulimia nervosa and its treatment. European Eating Disorders Review. 2001;9:182-193.
Robinson P, Serfaty M. Computers, e-mail and therapy in eating disorders. European Eating Disorders Review. 2003;11:210-221.
Robinson P, Serfaty M. Getting better byte by byte: A pilot randomised controlled trial of email therapy for bulimia nervosa and binge eating disorder. European Eating Disorders Review. 2008;16:84-93. [pmid: 17879223].
Robinson S, Perkins S, Bauer S, Hammond N, Treasure J, Schmidt U. Aftercare intervention through text messaging in the treatment of bulimia nervosa––Feasibility pilot. International Journal of Eating Disorders. 2006;39:633-638. [pmid: 16937381].
Robroek SJ, Brouwer W, Lindeboom D, Oenema A, Burdorf A. Demographic, behavioral, and psychosocial correlates of using the Website component of a worksite physical activity and healthy nutrition promotion program: A longitudinal study. Journal of Medical Internet Research. 2010;12:e44. [pmid: 20921001].
Robson D, Robson M. Ethical issues in Internet counselling. Counselling Psychology Quarterly. 2000;13:249-257.
Rochlen AB, Beretvas SN, Zack JS. The online and face-to-face counseling attitudes scales: A validation study. Measurement and Evaluation in Counseling and Development. 2004;37:95-111.
Rochlen AB, Land LN, Wong YJ. Male restrictive emotionality and evaluations of online versus face-to-face counseling. Psychology of Men & Masculinity. 2004;5:190-200.
Rochlen AB, Zack JS, Speyer C. Online therapy: Review of relevant definitions, debates, and current empirical support. Journal of Clinical Psychology. 2004;60:269-283. [pmid: 14981791].
Rockinson-Szapkiw AJ, Walker VL. Web 2.0 technologies: Facilitating interaction in an online human services counseling skills course. Journal of Technology in Human Services. 2009;27:175-193.
Rodda S, Lubman D. Ready to change: A scheduled telephone counselling programme for problem gambling. Australasian Psychiatry. 2012;20(4):338-342. [pmid: 22767931].
Rodgers A, Corbett T, Bramley D, Riddell T, Wills M, Lin RB, Jones M. Do u smoke after txt? Results of a randomised trial of smoking cessation using mobile phone text messaging. Tobacco Control. 2005;14:255-261. [pmid: 16046689].
Rodriguez MD, Favela J, Preciado A, Vizcaino A. Agent-based ambient intelligence for healthcare. AI Communications. 2005;18:201-216.
Rodriguez-Martos A, Castellano Y. Web-based screening and advice for hazardous drinkers: Use of a Spanish site. Drug and Alcohol Review. 2009;28:54-59. [pmid: 19320676].
Rohde P, Lewinsohn PM, Seeley JR. Comparability of telephone and face-to-face interviews in assessing axis I and II disorders. American Journal of Psychiatry. 1997;154:1593-1598. [pmid: 9356570].
Roker D, Coleman J. Education and advice about illegal drugs: What do young people want?. Drugs–Education Prevention and Policy. 1997;4:53-64.
Rooke S, Thorsteinsson E, Karpin A, Copeland J, Allsop D. Computer-delivered interventions for alcohol and tobacco use: A meta-analysis. Addiction. 2010;105:1381-1390. [pmid: 20528806].
Rosenberg JI. Real-time training: Transfer of knowledge through computer-mediated, real-time feedback. Professional Psychology: Research and Practice. 2006;37:539-546.
Rosik CH, Brown RK. Professional use of the Internet: Legal and ethical issues in a member care environment. Journal of Psychology and Theology. 2001;29:106-120.
Rosmarin DH, Pargament KI, Pirutinsky S, Mahoney A. A randomized controlled evaluation of a spiritually integrated treatment for subclinical anxiety in the Jewish community, delivered via the Internet. Journal of Anxiety Disorders. 2010;24:799-808. [pmid: 20591614].
Roth JD. Group psychotherapy (online): 12 steps into cyberspace. Addiction Professional. 2005;3:46-47.
Roth JD, Tan EM. Analysis of an online Al-Anon meeting. Journal of Groups in Addiction & Recovery. 2007;2:5-39.
Roth JD, Tan EM. Spirituality and recovery from familial aspects of alcohol and other drug problems: Analysis of an online Al-Anon meeting. Alcohol Treatment Quarterly. 2008;26:399-426.
Rothbaum BO, Hodges LF, Ready D, Graap K, Alarcon RD. Virtual reality exposure therapy for Vietnam veterans with posttraumatic stress disorder. Journal of Clinical Psychiatry. 2001;62:617-622. [pmid: 11561934].
Rothbaum BO, Rizzo AS, Difede J. Virtual reality exposure therapy for combat-related posttraumatic stress disorder. Annals of the New York Academy of Sciences. 2010;1208:126-132. [pmid: 20955334].
Rothert K, Strecher VJ, Doyle LA, Caplan WM, Joyce JS, Jimison HB, Roth MA. Web-based weight management programs in an integrated health care setting: A randomized, controlled trial. Obesity Research. 2006;14:266-272.
Rotondi AJ. Schizophrenia. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:69-89. New York. Routledge/Taylor & Francis Group.
Rotondi AJ, Anderson CM, Haas GL, Eack SM, Spring MB, Ganguli R, Rosenstock J. Web-based psychoeducational intervention for persons with schizophrenia and their supporters: One-year outcomes. Psychiatric Services. 2010;61:1099-1105. [pmid: 21041348].
Rotondi AJ, Sinkule J, Haas GL, Spring MB, Litschge CM, Newhill CE, Anderson CM. Designing Websites for persons with cognitive deficits: Design and usability of a psychoeducational intervention for persons with severe mental illness. Psychological Services. 2007;4:202-224. [pmid: 26321884].
Rotondi AJ, Sinkule J, Spring M. An interactive Web-based intervention for persons with TBI and their families: Use and evaluation by female significant others. Journal of Head Trauma Rehabilitation. 2005;20:173-185. [pmid: 15803040].
Rotondi AJ, Spring M, Grady J, Simpson R, Luther J, Abebe KZ, Haas GL. Use of a fractional factorial experiment to assess the e-healthcare application design needs of persons with dual diagnosis. Journal of Dual Diagnosis. 2012;8:277-282.
Rowland JL, White GW, Wyatt DA. Analysis of an intervention to reduce or prevent secondary conditions for people with spinal cord injuries. Journal of Clinical Psychology in Medical Settings. 2006;13:263-271.
Roy H, Gillett T. E-mail: A new technique for forming a therapeutic alliance with high-risk young people failing to engage with mental health services? A case study. Clinical Child Psychology and Psychiatry. 2008;13:95-103. [pmid: 18411868].
Roy MJ, Taylor P, Runge W, Grigsby E, Woolley M, Torgeson T. Web-based post-traumatic stress disorder education for military family members. Military Medicine. 2012;177:284-290. [pmid: 22479915].
Roy-Byrne P, Craske MG, Sullivan G, Rose RD, Edlund MJ, Lang AJ, Stein MB. Delivery of evidence-based treatment for multiple anxiety disorders in primary care: A randomized controlled trial. JAMA. 2010;303:1921-1928. [pmid: 20483968].
Ruetsch C, Cacciola J, Tkacz J. A national study of a telephone support service for patients receiving office-based buprenorphine medication–assisted treatment: Study feasibility and sample description. Journal of Substance Abuse Treatment. 2010;39:307-317. [pmid: 20728299].
Ruetsch C, Tkacz J, McPherson TL, Cacciola J. The effect of telephonic patient support on treatment for opioid dependence: Outcomes at one year follow-up. Addictive Behaviors. 2012;37:686-689. [pmid: 22348921].
Ruggiero KJ, Resnick HS, Acierno R, Carpenter MJ, Kilpatrick DG, Coffey SF, Galea S. Internet-based intervention for mental health and substance use problems in disaster-affected populations: A pilot feasibility study. Behavior Therapy. 2006;37:190-205. [pmid: 16942971].
Runge C, Lecheler J, Horn M, Tews JT, Schaefer M. Outcomes of a Web-based patient education program for asthmatic children and adolescents. Chest. 2006;129:581-593. [pmid: 16537855].
Ruskin PE, Silver-Aylaian M, Kling MA, Reed SA, Bradham DD, Hebel JR, Hauser P. Treatment outcomes in depression: Comparison of remote treatment through telepsychiatry to in-person treatment. American Journal of Psychiatry. 2004;161:1471-1476. [pmid: 15285975].
Ruskin PE, Van Der Wende J, Clark CR, Fenton J, Deveau J, Thapar R. Feasibility of using the Med-eMonitor system in the treatment of schizophrenia: A pilot study. Drug Information Journal. 2003;37:283-291.
Ruwaard J, Broeksteeg J, Schrieken B, Emmelkamp P, Lange A. Web-based therapist-assisted cognitive behavioral treatment of panic symptoms: A randomized controlled trial with a three-year follow-up. Journal of Anxiety Disorders. 2010;24:387-396. [pmid: 20227241].
Ruwaard J, Lange A, Bouwman M, Broeksteeg J, Schrieken B. E-mailed standardized cognitive behavioural treatment of work-related stress: A randomized controlled trial. Cognitive Behaviour Therapy. 2007;36:179-192. [pmid: 17852171].
Ruwaard J, Lange A, Schrieken B, Emmelkamp P. Efficacy and effectiveness of online cognitive behavioral treatment: A decade of interapy research. Studies in Health Technology and Informatics. 2011;167:9-14. [pmid: 21685634].
Rydell SA, French SA, Fulkerson JA, Neumark-Sztainer D, Gerlach AF, Story M, Christopherson KK. Use of a Web-based component of a nutrition and physical activity behavioral intervention with Girl Scouts. Journal of the American Dietetic Association. 2005;105:1447-1450. [pmid: 16129089].
Sablier J, Stip E, Jacquet P, Giroux S, Pigot H, Franck N. Ecological assessments of activities of daily living and personal experiences with Mobus, an assistive technology for cognition: A pilot study in schizophrenia. Assistive Technology. 2012;24:67-77. [pmid: 22876729].
Sachpazidis I, Majadas M. A medication adherence monitoring system based on HL7 messages. Journal on Information Technology in Healthcare. 2006;4:49-58.
Sadan B. Patient empowerment and the asymmetry of knowledge. Studies in Health Technology and Informatics. 2002;90:514-518. [pmid: 15460747].
Saitz R, Helmuth ED, Aromaa SE, Guard A, Belanger M, Rosenbloom DL. Web-based screening and brief intervention for the spectrum of alcohol problems. Preventive Medicine. 2004;39:969-975. [pmid: 15475031].
Saitz R, Palfai TP, Freedner N, Winter MR, MacDonald A, Lu J, Dejong W. Screening and brief intervention online for college students: The iHealth study. Alcohol and Alcoholism. 2007;42:28-36. [pmid: 17130139].
Salem DA, Bogat GA, Reid C. Mutual help goes on-line. Journal of Community Psychology. 1997;25:189-207.
Salemink E, van den Hout M, Kindt M. Trained interpretive bias: Validity and effects on anxiety. Journal of Behavior Therapy and Experimental Psychiatry. 2007;38:212-224. [pmid: 17141735].
Salemink E, van den Hout M, Kindt M. Effects of positive interpretive bias modification in highly anxious individuals. Journal of Anxiety Disorders. 2009;23:676-683. [pmid: 19272750].
Samoocha D, Bruinvels DJ, Elbers NA, Anema JR, van der Beek AJ. Effectiveness of Web-based interventions on patient empowerment: A systematic review and meta-analysis. Journal of Medical Internet Research. 2010;12:e23. [pmid: 20581001].
Sampson JP. Quality and ethics in Internet-based guidance. International Journal for Educational and Vocational Guidance. 2002;2:157-171.
Sampson JP, Kolodinsky RW, Greeno BP. Counseling and the information highway: Future possibilities and potential problems. Journal of Counseling & Development. 1997;75:203-212.
Sánchez-Ortiz VC, House J, Munro C, Treasure J, Startup H, Williams C, Schmidt U. “A computer isn't gonna judge you”: A qualitative study of users' views of an Internet-based cognitive behavioural guided self-care treatment package for bulimia nervosa and related disorders. Eating and Weight Disorders. 2011;16:e93-e101. [pmid: 21989103].
Sánchez-Ortiz VC, Munro C, Stahl D, House J, Startup H, Treasure J, Schmidt U. A randomized controlled trial of Internet-based cognitive-behavioural therapy for bulimia nervosa or related disorders in a student population. Psychological Medicine. 2011;41:407-417. [pmid: 20406523].
Sanchez-Page D. The online-counseling debate: A view toward the underserved. Counseling Psychologist. 2005;33:891-899.
Sander FM. Couples group therapy conducted via computer-mediated communication: A preliminary case study. Computers in Human Behavior. 1996;12:301-312.
Sanders P, Rosenfield M. Counselling at a distance: Challenges and new initiatives. British Journal of Guidance & Counselling. 1998;26:5-10.
Sands DZ. Help for physicians contemplating use of e-mail with patients. Journal of the American Medical Informatics Association. 2004;11:268-269. [pmid: 15252925].
Santangelo P, Bohus M, Ebner-Priemer UW. Ecological momentary assessment in borderline personality disorder: A review of recent findings and methodological challenges. Journal of Personality Disorders. 2014;28(4):555-576. [pmid: 22984853].
Santhiveeran J. Compliance of social work e-therapy Websites to the NASW Code of Ethics. Social Work in Health Care. 2009;48:1-13. [pmid: 19197763].
Santor DA, Poulin C, LeBlanc JC, Kusumakar V. Online health promotion, early identification of difficulties, and help seeking in young people. Journal of the American Academy of Child and Adolescent Psychiatry. 2007;46:50-59. [pmid: 17195729].
Saul JE, Schillo BA, Evered S, Luxenberg MG, Kavanaugh A, Cobb N, An AC. Impact of a statewide Internet-based tobacco cessation intervention. Journal of Medical Internet Research. 2007;9:e28. [pmid: 17942390].
Schatz B, Kumar S, Silverstein J, Krishnan J. 2012. Panel proposal: Measuring data for population health: New information systems for new health systems. Urbana, IL. College of Engineering, University of Illinois at Urbana-Champaign.
Scherl CR, Haley J. Computer monitor supervision: A clinical note. American Journal of Family Therapy. 2000;28:275-282.
Schinke SP, Fang L, Cole KC, Cohen-Cutler S. Preventing substance use among black and Hispanic adolescent girls: Results from a computer-delivered, mother–daughter intervention approach. Substance Use & Misuse. 2011;46:35-45. [pmid: 21190404].
Schinke S, Schwinn T, Cole K. Preventing alcohol abuse among early adolescents through family and computer-based interventions: Four-year outcomes and mediating variables. Journal of Developmental and Physical Disabilities. 2006;18:149-161. [pmid: 17215960].
Schinke SP, Schwinn TM, Di Noia J, Cole KC. Reducing the risks of alcohol use among urban youth: Three-year effects of a computer-based intervention with and without parent involvement. Journal of Studies on Alcohol. 2004;65:443-449. [pmid: 15376818].
Schinke SP, Schwinn TM, Ozanian AJ. Alcohol abuse prevention among high-risk youth: Computer-based intervention. Journal of Prevention & Intervention in the Community. 2005;29:117-130. [pmid: 16804562].
Schmelz AN, Nixon B, McDaniel A, Hudmon KS, Zillich AJ. Evaluation of an online tobacco cessation course for health professions students. American Journal of Pharmaceutical Education. 2010;74:36. [pmid: 20414451].
Schmid-Siegel B, Stompe T, Ortwein-Swoboda G. Being a Webcam. Psychopathology. 2004;37:84-85. [pmid: 15057033].
Schmidt NB, Richey JA, Buckner JD, Timpano KR. Attention training for generalized social anxiety disorder. Journal of Abnormal Psychology. 2009;118:5-14. [pmid: 19222309].
Schneider AJ, Mataix-Cols D, Marks IM, Bachofen M. Internet-guided self-help with or without exposure therapy for phobic and panic disorders. Psychotherapy and Psychosomatics. 2005;74:154-164. [pmid: 15832066].
Schoenberg MR, Ruwe WD, Dawson K, McDonald NB, Houston B, Forducey PG. Comparison of functional outcomes and treatment cost between a computer-based cognitive rehabilitation teletherapy program and a face-to-face rehabilitation program. Professional Psychology: Research and Practice. 2008;39:169-175.
Schofield JW, Davidson AL. Achieving equality of student Internet access within schools. Eagly AH, Baron RM, editors. The social psychology of group identity and social conflict: Theory, application, and practice. 2004:97-109. Washington, DC. American Psychological Association.
Schuemie MJ, van der Straaten P, Krijn M, van der Mast CA. Research on presence in virtual reality: A survey. CyberPsychology & Behavior. 2001;4:183-201. [pmid: 11710246].
Schultze NG. Success factors in Internet-based psychological counseling. CyberPsychology and Behavior. 2006;9:623-626. [pmid: 17034332].
Schulz PJ, Hulsman RL. Assessing the quality of eHealth programs and their impact on health behaviour and health outcomes of users. Patient Education and Counseling. 2009;77:1-3. [pmid: 19723596].
Schumann A, John U, Baumeister SE, Ulbricht S, Rumpf HJ, Meyer C. Computer-tailored smoking cessation intervention in a general population setting in Germany: Outcome of a randomized controlled trial. Nicotine and Tobacco Research. 2008;10:371-379. [pmid: 18236302].
Schwinn TM, Schinke SP, Di Noia J. Preventing drug abuse among adolescent girls: Outcome data from an Internet-based intervention. Prevention Science. 2010;11:24-32. [pmid: 19728091].
Scott CK, Dennis ML, Foss MA. Utilizing recovery management checkups to shorten the cycle of relapse, treatment reentry, and recovery. Drug and Alcohol Dependence. 2005;78:325-338. [pmid: 15893164].
Scott D, Rosen H, Tritle B, Kanwal S, Brown M, Clark A, Hoover W. 2011. Top ten things you need to know about engaging patients. New York. Institute for Health Technology Transformation.
Seal KH, Abadjian L, McCamish N, Shi Y, Tarasovsky G, Weingardt K. A randomized controlled trial of telephone motivational interviewing to enhance mental health treatment engagement in Iraq and Afghanistan veterans. General Hospital Psychiatry. 2012;34(5):450-459. [pmid: 22632925].
Seale C. Portrayals of treatment decision-making on popular breast and prostate cancer Web sites. European Journal of Cancer Care. 2005;14:171-174. [pmid: 15842467].
Secure Telehealth. 2012. Medicaid reimburses for telepsychiatry in 40 states. Pittsburgh, PA. Author.
Seidman DF, Westmaas JL, Goldband S, Rabius V, Katkin ES, Pike KJ, Sloan RP. Randomized controlled trial of an interactive Internet smoking cessation program with long-term follow-up. Annals of Behavioral Medicine. 2010;39:48-60. [pmid: 20177844].
Selby P, Van Mierlo T, Voci SC, Parent D, Cunningham JA. Online social and professional support for smokers trying to quit: An exploration of first time posts from 2562 members. Journal of Medical Internet Research. 2010;12:e34. [pmid: 20719739].
Seligman ME, Rashid T, Parks AC. Positive psychotherapy. American Psychologist. 2006;61:774-788. [pmid: 17115810].
Seligman MEP, Steen TA, Park N, Peterson C. Positive psychology progress: Empirical validation of interventions. American Psychologist. 2005;60:410-421. [pmid: 16045394].
Sellers B, Galanter M, Dermatis H, Nachbar M. Enhancing physicians' use of Alcoholics Anonymous: Internet-based training. Journal of Addictive Diseases. 2005;24:77-86. [pmid: 16186084].
Selmi PM, Klein MH, Greist JH, Sorrell SP, Erdman HP. Computer-administered cognitive-behavioral therapy for depression. American Journal of Psychiatry. 1990;147:51-56. [pmid: 2403473].
Selmi PM, Klein MH, Greist JH, Sorrell SP, Erdman HP. Computer-administered therapy for depression. MD Computing. 1991;8:98-102. [pmid: 2038242].
Senior C, Hunter E, Lambert MV, Medford NC, Sierra M, Phillips ML, David AS. Depersonalisation. Psychologist. 2001;14:128-132.
Serre F, Fatseas M, Debrabant R, Alexandre JM, Auriacombe M, Swendsen J. Ecological momentary assessment in alcohol, tobacco, cannabis and opiate dependence: A comparison of feasibility and validity. Drug and Alcohol Dependence. 2012;126:118-123. [pmid: 22647899].
Severson HH, Gordon JS, Danaher BG, Akers L. ChewFree.com: Evaluation of a Web-based cessation program for smokeless tobacco users. Nicotine and Tobacco Research. 2008;10:381-391. [pmid: 18236303].
Sexton MB, Byrd MR, O'Donohue WT, Jacobs NN. Web-based treatment for infertility-related psychological distress. Archives of Women's Mental Health. 2010;13:347-358.
Shahab L, McEwen A. Online support for smoking cessation: A systematic review of the literature. Addiction. 2009;104:1792-1804. [pmid: 19832783].
Shandley K, Austin D, Klein B, Kyrios M. An evaluation of ‘Reach Out Central’: An online gaming program for supporting the mental health of young people. Health Education Research. 2010;25:563-574. [pmid: 20150530].
Shandley K, Austin WD, Klein B, Pier C, Schattner P, Pierce D, Wade V. Therapist-assisted, Internet-based treatment for panic disorder: Can general practitioners achieve comparable patient outcomes to psychologists?. Journal of Medical Internet Research. 2008;10:e14. [pmid: 18487138].
Shapiro DE, Schulman CE. Ethical and legal issues in e-mail therapy. Ethics and Behavior. 1996;6:107-124. [pmid: 11654969].
Shapiro JR, Bauer S, Hamer RM, Kordy H, Ward D, Bulik CM. Use of text messaging for monitoring sugar-sweetened beverages, physical activity, and screen time in children: A pilot study. Journal of Nutrition Education and Behavior. 2008;40:385-391. [pmid: 18984496].
Shapiro JR, Reba-Harrelson L, Dymek-Valentine M, Woolson SL, Hamer RM, Bulik CM. Feasibility and acceptability of CD-ROM-based cognitive-behavioural treatment for binge-eating disorder. European Eating Disorders Review. 2007;15:175-184. [pmid: 17676687].
Sharp IR, Kobak KA, Osman DA. The use of videoconferencing with patients with psychosis: A review of the literature. Annals of General Psychiatry. 2011;10:14. [pmid: 21501496].
Shaw HE, Shaw SF. Critical ethical issues in online counseling: Assessing current practices with an ethical intent checklist. Journal of Counseling and Development. 2006;84:41-53.
Shek DT, Tang VM, Lo CY. Evaluation of an Internet addiction treatment program for Chinese adolescents in Hong Kong. Adolescence. 2009;44:359-373. [pmid: 19764272].
Shepherd L, Goldstein D, Olver I, Parle M. Enhancing psychosocial care for people with cancer in rural communities: What can remote counselling offer?. Australian Health Review. 2008;32:423-438. [pmid: 18666870].
Shibusawa T, VanEsselstyn D, Oppenheim S. Third space: A Web-based learning environment for teaching advanced clinical practice skills. Journal of Technology in Human Services. 2006;24:21-33.
Shiffman S. Ecological momentary assessment (EMA) in studies of substance use. Psychological Assessment. 2009;21:486-497. [pmid: 19947783].
Shimazu A, Kawakami N, Irimajiri H, Sakamoto M, Amano S. Effects of Web-based psychoeducation on self-efficacy, problem solving behavior, stress responses and job satisfaction among workers: A controlled clinical trial. Journal of Occupational Health. 2005;47:405-413. [pmid: 16230834].
Shoham A. Flow experiences and image making: An online chat-room ethnography. Psychology and Marketing. 2004;21:855-882.
Sholomskas DE, Syracuse-Siewert G, Rounsaville BJ, Ball SA, Nuro KF, Carroll KM. We don't train in vain: A dissemination trial of three strategies of training clinicians in cognitive-behavioral therapy. Journal of Consulting and Clinical Psychology. 2005;73:106-115. [pmid: 15709837].
Shore JH, Brooks E, Anderson H, Bair B, Dailey N, Kaufmann LJ, Manson S. Characteristics of telemental health service use by American Indian veterans. Psychiatric Services. 2012;63:179-181. [pmid: 22302338].
Shore JH, Hilty DM, Yellowlees P. Emergency management guidelines for telepsychiatry. General Hospital Psychiatry. 2005;29:199-206. [pmid: 17484936].
Shore JH, Kaufmann LJ, Brooks E, Bair B, Dailey N, Richardson WJ, Manson S. Review of American Indian veteran telemental health. Telemedicine and e-Health. 2012;18:87-94. [pmid: 22283396].
Shore JH, Savin DM, Novins D, Manson SM. Cultural aspects of telepsychiatry. Journal of Telemedicine and Telecare. 2006;12:116-121. [pmid: 16638232].
Shore JH, Savin D, Orton H, Beals J, Manson SM. Diagnostic reliability of telepsychiatry in American Indian veterans. American Journal of Psychiatry. 2007;164:115-118. [pmid: 17202552].
Shore JH, Thurman MT, Fujinami L, Brooks E, Nagamoto H. A resident, rural telepsychiatry service: Training and improving care for rural populations. Academic Psychiatry. 2011;35:252-255. [pmid: 21804046].
Shpigelman CN, Reiter S, Weiss PL. A conceptual framework for electronic socio-emotional support for people with special needs. International Journal of Rehabilitation Research. 2009;32:301-308. [pmid: 19901617].
Shpigelman CN, Weiss PL, Reiter S. E-mentoring for all. Computers in Human Behavior. 2009;25:919-928.
Shtayermman O. Peer victimization in adolescents and young adults diagnosed with Asperger's Syndrome: A link to depressive symptomatology, anxiety symptomatology and suicidal ideation. Issues in Comprehensive Pediatric Nursing. 2007;30:87-107. [pmid: 17885828].
Siegel AM, Topel EM. eSupervision: Something new under the sun. Goldberg A, editor. Progress in self psychology: Vol. 16. How responsive should we be?. 2000:103-139. Mahwah, NJ. Analytic Press.
Sillence E, Briggs P. Please advise: Using the Internet for health and financial advice. Computers in Human Behavior. 2007;23:727-748.
Silverman K, Wong CJ, Grabinski MJ, Hampton J, Sylvest CE, Dillon EM, Wentland RD. A Web-based therapeutic workplace for the treatment of drug addiction and chronic unemployment. Behavior Modification. 2005;29:417-463. [pmid: 15657415].
Simon GE, Ludman EJ, Goodale LC, Dykstra DM, Stone E, Cutsogeorge D, Pabiniak C. An online recovery plan program: Can peer coaching increase participation?. Psychiatric Services. 2011;62:666-669. [pmid: 21632737].
Simon GE, Ludman EJ, Rutter CM. Incremental benefit and cost of telephone care management and telephone psychotherapy for depression in primary care. Archives of General Psychiatry. 2009;66:1081-1089. [pmid: 19805698].
Simon GE, Ludman EJ, Tutty S, Operskalski B, Von Korff M. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: A randomized controlled trial. JAMA. 2004;292:935-942. [pmid: 15328325].
Simon GE, Ralston JD, Savarino J, Pabiniak C, Wentzel C, Operskalski BH. Randomized trial of depression follow-up care by online messaging. Journal of General Internal Medicine. 2011;26:698-704. [pmid: 21384219].
Simon GE, Revicki D, Von Korff M. Telephone assessment of depression severity. Journal of Psychiatric Research. 1993;27:247-252. [pmid: 8295157].
Simon-Arndt CM, Hurtado SL, Patriarca-Troyk LA. Acceptance of Web-based personalized feedback: User ratings of an alcohol misuse prevention program targeting U.S. Marines. Health Community. 2006;20:13-22.
Simpson RL. IT matters in behavioral health. Nursing Administration Quarterly. 2007;31:254-263. [pmid: 17607138].
Simpson S. Psychotherapy via videoconferencing: A review. British Journal of Guidance and Counselling. 2009;37:271-286.
Simpson S, Morrow E. Using videoconferencing for conducting a therapeutic relationship. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:94-103. Springfield, IL. Charles C. Thomas Publisher.
Simpson TL, Galloway C, Rosenthal CF, Bush KR, McBride B, Kivlahan DR. Daily telephone monitoring compared with retrospective recall of alcohol use among patients in early recovery. American Journal on Addictions. 2011;20:63-68. [pmid: 21175922].
Sims TH, McAfee T, Fraser DL, Baker TB, Fiore MC, Smith SS. Quitline cessation counseling for young adult smokers: A randomized clinical trial. Nicotine and Tobacco Research. 2012;15(5):932-941. [pmid: 23080378].
Sinadinovic K, Berman AH, Hasson D, Wennberg P. Internet-based assessment and self-monitoring of problematic alcohol and drug use. Addictive Behaviors. 2010;35:464-470. [pmid: 20092953].
Singh H, Fox AS, Petersen JN, Shethia A, Street LR. Older patients' enthusiasm to use electronic mail to communicate with their physicians: Cross-sectional survey. Journal of Medical Internet Research. 2009;11:e18. [pmid: 19632972].
Singh SP, Arya D, Peters T. Accuracy of telepsychiatric assessment of new routine outpatient referrals. BMC Psychiatry. 2007;7:55. [pmid: 17919329].
Skårderud F. Sh@me in cyberspace. Relationships without faces: The e-media and eating disorders. European Eating Disorders Review. 2003;11:155-169.
Skinner A, Zack JS. Counseling and the Internet. American Behavioral Scientist. 2004;48:434-446.
Skinner AEG, Latchford G. International and multicultural issues in online counseling. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:241-254. New York. Elsevier Science.
Skinner AEG, Latchford G. Attitudes to counselling via the Internet: A comparison between in-person counselling clients and Internet support group users. Counselling and Psychotherapy Research. 2006;6:158-163.
Skinner AEG, Latchford G. International and multicultural issues in online counseling. Kraus R, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2nd ed. 2011:257-269. Elsevier Inc.
Skinner HA, Maley O, Norman CD. Developing Internet-based ehealth promotion programs: The Spiral Technology Action Research (STAR) model. Health Promotion Practice. 2006;7:406-417. [pmid: 16840770].
Skinner H, Maley O, Smith L, Chirrey S, Morrison M. New frontiers: Using the Internet to engage teens in substance abuse prevention and treatment. Monti PM, Colby SM, O'Leary T, editors. Adolescents, alcohol and substance abuse: Reaching teens through brief interventions. 2001:297-318. New York. The Guilford Press.
Skuse D. Psychiatry and the Internet: A new dawn?. Psychiatric Bulletin. 2004;28:2-3.
Slack WV. The patient online. American Journal of Preventive Medicine. 1999;16:43-45. [pmid: 9894554].
Slakey DP, Nowfar S. Factors affecting patient–physician communication via the Internet. Journal of Healthcare Information Management. 2004;18:81-85. [pmid: 14971084].
Sloan DM, Gallagher MW, Feinstein BA, Lee DJ, Pruneau GM. Efficacy of telehealth treatments for posttraumatic stress-related symptoms: A meta-analysis. Cognitive Behaviour Therapy. 2011;40:111-125. [pmid: 21547778].
Smit ES, de Vries H, Hoving C. The PAS study: A randomized controlled trial evaluating the effectiveness of a Web-based multiple tailored smoking cessation programme and tailored counselling by practice nurses. Contemporary Clinical Trials. 2010;31:251-258. [pmid: 20215047].
Smith A. 2010. Home broadband 2010. Washington, DC. Pew Research Center.
Smith A, Rainie L, Zickuhr K. 2011. College students and technology. Washington, DC. Pew Internet and American Life Project.
Smith B, Harms WD, Burres S, Korda H, Rosen H, Davis J. Enhancing behavioral health treatment and crisis management through mobile ecological momentary assessment and SMS messaging. Health Informatics Journal. 18:294-308. [pmid: 23257059].
Smith DJ, Griffiths E, Poole R, di Florio A, Barnes E, Kelly MJ, Simpson S. Beating bipolar: Exploratory trial of a novel Internet-based psychoeducational treatment for bipolar disorder. Bipolar Disorders. 2011;13:571-577. [pmid: 22017225].
Smith JL, Carpenter KM, Amrhein PC, Brooks AC, Levin D, Schreiber EA, Nunes EV. Training substance abuse clinicians in motivational interviewing using live supervision via teleconferencing. Journal of Consulting and Clinical Psychology. 2012;80:450-464. [pmid: 22506795].
Smith MA, Senior C. The Internet and clinical psychology: A general review of the implications. Clinical Psychology Review. 2001;21:129-136. [pmid: 11148893].
Smith SD, Reynolds C. Cyber-psychotherapy. Annals of the American Psychotherapy Association. 2002;5:20-22.
Smith-Hansen L, Constantino MJ, Piselli A, Remen AL. Preliminary results of a video-assisted psychotherapist workshop in alliance strategies. Psychotherapy. 2011;48:148-162. [pmid: 21639658].
Smolkowski K, Danaher BG, Seeley JR, Kosty DB, Severson HH. Modeling missing binary outcome data in a successful Web-based smokeless tobacco cessation program. Addiction. 2010;105:1005-1015. [pmid: 20148782].
Sobel NR. Treatment: Online rehab—Are you connected?. Counselor. 2009;10:26-27.
Sobell LC, Brown J, Leo GI, Sobell MB. The reliability of the Alcohol Timeline Followback when administered by telephone and by computer. Drug and Alcohol Dependence. 1996;42:49-54. [pmid: 8889403].
Sorbi MJ, van der Vaart R. User acceptance of an Internet training aid for migraine self-management. Journal of Telemedicine and Telecare. 2010;16:20-24. [pmid: 20086263].
Sorvaniemi M, Ojanen E, Santamäki O. Telepsychiatry in emergency consultations: A follow-up study of sixty patients. Telemedicine Journal and e-Health. 2005;11:439-441. [pmid: 16149889].
Southern S. Treatment of compulsive cybersex behavior. Psychiatric Clinics of North America. 2008;31:697-712. [pmid: 18996308].
Spek V, Cuijpers P, Nyklíček I, Riper H, Keyzer J, Pop V. Internet-based cognitive behaviour therapy for symptoms of depression and anxiety: A meta-analysis. Psychological Medicine. 2007;37:319-328. [pmid: 17112400].
Spek V, Cuijpers P, Nyklíček I, Smits N, Riper H, Keyzer J, Pop V. One-year follow-up results of a randomized controlled clinical trial on Internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years. Psychological Medicine. 2008;38:635-639. [pmid: 18205965].
Spek V, Nyklíček I, Cuijpers P, Pop V. Predictors of outcome of group and Internet-based cognitive behavior therapy. Journal of Affective Disorders. 2008;105:137-145. [pmid: 17543392].
Spek V, Nyklíček I, Smits N, Cuijpers P, Riper H, Keyzer J, Pop V. Internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years old: A randomized controlled clinical trial. Psychological Medicine. 2007;37:1797-1806. [pmid: 17466110].
Spence J, Titov N, Dear BF, Johnston L, Solley K, Lorian C, Schwenke G. Randomized controlled trial of Internet-delivered cognitive behavioral therapy for posttraumatic stress disorder. Depression and Anxiety. 2011;28:541-550. [pmid: 21721073].
Spence SH, Donovan CL, March S, Gamble A, Anderson R, Prosser S, Kenardy J. Online CBT in the treatment of child and adolescent anxiety disorders: Issues in the development of BRAVE-ONLINE and two case illustrations. Behavioural and Cognitive Psychotherapy. 2008;36:411-430.
Spence SH, Holmes JM, March S, Lipp OV. The feasibility and outcome of clinic plus Internet delivery of cognitive–behavior therapy for childhood anxiety. Journal of Consulting and Clinical Psychology. 2006;74:614-621. [pmid: 16822117].
Squires DD, Bryant MD. Substance use disorders. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:91-108. New York. Routledge/Taylor & Francis Group.
Squires DD, Hester RK. Development of a computer-based, brief intervention for drinkers: The increasing role of computers in the assessment and treatment of addictive behaviors. The Behavior Therapist. 2002;25:59-65.
Stamm BH. Clinical applications of telehealth in mental health care. Professional Psychology: Research and Practice. 1998;29:536-542.
Stead LF, Perera R, Lancaster T. Telephone counselling for smoking cessation. Cochrane Database of Systematic Reviews. 2006;3. CD002850.
Stead LF, Perera R, Lancaster T. A systematic review of interventions for smokers who contact quitlines. Tobacco Control. 2007;16(Suppl 1):i3-i8. [pmid: 18048627].
Stebnicki MA, Glover NM. E-supervision as a complementary approach to traditional face-to-face clinical supervision in rehabilitation counseling: Problems and solutions. Rehabilitation Education. 2001;15:283-293.
Steel C, Wykes T, Ruddle A, Smith G, Shah DM, Holmes EA. Can we harness computerised cognitive bias modification to treat anxiety in schizophrenia? A first step highlighting the role of mental imagery. Psychiatry Research. 2010;178:451-455. [pmid: 20553826].
Steinmark AP, Dornelas EA, Fischer EH. Determinants and barriers to participation in an Internet based recovery program for cardiac patients. Journal of Clinical Psychology in Medical Settings. 2006;13:353-357.
Stellefson M, Hanik B, Chaney B, Chaney D, Tennant B, Chavarria EA. eHealth literacy among college students: A systematic review with implications for eHealth education. Journal of Medical Internet Research. 2011;13:e102. [pmid: 22155629].
Stephens-Reicher J, Metcalf A, Blanchard M, Mangan C, Burns J. Reaching the hard-to-reach: How information communication technologies can reach young people at greater risk of mental health difficulties. Australasian Psychiatry. 2011;19:S58-S61. [pmid: 21878021].
Stern SA, Meridith LS, Gholson J, Gore P, D'Amico EJ. Project CHAT: A brief motivational substance abuse intervention for teens in primary care. Journal of Substance Abuse Treatment. 2007;32:153-165. [pmid: 17306724].
Stevens JV, Funk LK, Brantley JP, Erlinger PT, Myers HV, Champagne MC, Hollis JF. Design and implementation of an interactive Website to support long-term maintenance of weight loss. Journal of Medical Internet Research. 2008;10:e1. [pmid: 18244892].
Stinson J, Wilson R, Gill N, Yamada J, Holt J. A systematic review of Internet-based self-management interventions for youth with health conditions. Journal of Pediatric Psychology. 2009;34:495-510. [pmid: 19029142].
Stjernsward S, Ostman M. Potential of e-health in relation to depression: Short survey of previous research. Journal of Psychiatric and Mental Health Nursing. 2006;13:698-703. [pmid: 17087672].
Stjernsward S, Ostman M. Depression, e-health and family support. What the Internet offers the relatives of depressed persons. Nordic Journal of Psychiatry. 2007;61:12-18. [pmid: 17365784].
Stjernsward S, Ostman M, Lowgren J. Online self-help tools for the relatives of persons with depression-A feasibility study. Scandinavian Journal of Caring Sciences. 2012;26:70-80. [pmid: 21692824].
Stoddard JL, Augustson EM, Moser RP. Effect of adding a virtual community (bulletin board) to smokefree.gov: Randomized controlled trial. Journal of Medical Internet Research. 2008;10:e53. [pmid: 19097974].
Stoddard J, Delucchi K, Muñoz R, Collins N, Stable EP, Augustson E, Lenert L. Smoking cessation research via the Internet: A feasibility study. Journal of Health Communication. 2005;10:27-41. [pmid: 15764442].
Stofle GS. Chat room therapy. Hsiung RC, editor. e-Therapy: Case studies, guiding principles, and the clinical potential of the Internet. 2002:92-135. New York. W W Norton & Co.
Stofle GS. Addiction treatment online. Behavioral Health Management. 2004;24:53-55.
Stofle GS, Chechele PJ. Online counseling skills, part II: In-session skills. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:181-196. New York. Elsevier Science.
Stofle GS, Harrington S. Treating addictions on the Internet: Can it be done? A dialogue. Journal of Social Work Practice in the Addictions. 2002;2:85-92.
Stoops WW, Dallery J, Fields NM, Nuzzo PA, Schoenberg NE, Martin CA, Wong CJ. An Internet-based abstinence reinforcement smoking cessation intervention in rural smokers. Drug and Alcohol Dependence. 2009;105:56-62. [pmid: 19615830].
Stout RL, Rubin A, Zwick W, Zywiak W, Bellino L. Optimizing the cost-effectiveness of alcohol treatment: A rationale for extended case monitoring. Addictive Behaviors. 1999;24:17-35. [pmid: 10189970].
Strassle CG, Borckardt JJ, Handler L, Nash M. Video-tape role induction for psychotherapy: Moving forward. Psychotherapy. 2011;48:170-178. [pmid: 21639660].
Strecher VJ. Internet methods for delivering behavioral and health-related interventions (eHealth). Annual Review of Clinical Psychology. 2007;3:53-76.
Strecher VJ. The Internet: Just another smoking cessation tool?. Addiction. 2008;103:485-486.
Strecher VJ, McClure JB, Alexander GL, Chakraborty B, Nair VN, Konkel JM, Pomerleau OF. Web-based smoking-cessation programs: Results of a randomized trial. American Journal of Preventive Medicine. 2008;34:373-381. [pmid: 18407003].
Strecher VJ, Shiffman S, West R. Randomized controlled trial of a Web-based computer-tailored smoking cessation program as a Suppl to nicotine patch therapy. Addiction. 2005;100:682-688. [pmid: 15847626].
Strecher VJ, Shiffman S, West R. Moderators and mediators of a Web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine and Tobacco Research. 2006;8:S95-S101. [pmid: 17491176].
Street RL Jr. Mediated consumer-provider communication in cancer care: The empowering potential of new technologies. Patient Education and Counseling. 2003;50:99-104. [pmid: 12767594].
Strom L, Pettersson R, Andersson G. Internet-based treatment for insomnia: A controlled evaluation. Journal of Consulting and Clinical Psychology. 2004;72:113-120. [pmid: 14756620].
Stuhlmiller C, Tolchard B. Computer-assisted CBT for depression and anxiety: Increasing accessibility to evidence-based mental health treatment. Journal of Psychosocial Nursing and Mental Health Services. 2009;47:32-39. [pmid: 19678477].
Styra R. The Internet's impact on the practice of psychiatry. Canadian Journal of Psychiatry/La Revue canadienne de psychiatrie. 2004;49:5-11.
Substance Abuse and Mental Health Services Administration. 2011. Addressing viral hepatitis in people with substance use disorders. Treatment Improvement Protocol (TIP) Series 53. HHS Publication No. SMA 11-4656. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Managing chronic pain in adults with or in recovery from substance use disorders. Treatment Improvement Protocol (TIP) Series 54. HHS Publication No. SMA 11-4661. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Addressing the specific behavioral health needs of men. Treatment Improvement Protocol (TIP) Series 56. HHS Publication No. SMA 13-4736. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Behavioral health services for people who are homeless. Treatment Improvement Protocol (TIP) Series 55. HHS Publication No. SMA 13-4734. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2014. Improving cultural competence. Treatment Improvement Protocol (TIP) Series 59. HHS Publication No. SMA 14-4849. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2014. Trauma-informed care in behavioral health services. Treatment Improvement Protocol (TIP) Series 57. HHS Publication No. SMA 14-4816. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration (planned a). Behavioral health services: Building health, wellness, and quality of life for sustained recovery. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned b). Behavioral health services for American Indians and Alaska Natives. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned c). Managing anxiety symptoms in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned d). Reintegration-related behavioral health issues in veterans and military families. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned e). Relapse prevention and recovery promotion in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Sucala M, Schnur JB, Constantino MJ, Miller SJ, Brackman EH, Montgomery GH. The therapeutic relationship in e-therapy for mental health: A systematic review. Journal of Medical Internet Research. 2012;14:e110. [pmid: 22858538].
Sugarman DE, Nich C, Carroll KM. Coping strategy use following computerized cognitive–behavioral therapy for substance use disorders. Psychology of Addictive Behaviors. 2010;24:689-695. [pmid: 21198228].
Suggs LS, McIntyre C. Are we there yet? An examination of online tailored health communication. Health Education and Behavior. 2009;36:278-288. [pmid: 17620667].
Suler J. Psychotherapy in cyberspace: A 5-dimensional model of online and computer-mediated psychotherapy. CyberPsychology and Behavior. 2000;3:151-159.
Suler J. Assessing a person's suitability for online therapy: The ISMHO clinical case study group. CyberPsychology and Behavior. 2001;4:675-679. [pmid: 11800174].
Suler J. The online clinical case study group: An e-mail model. Cyber Psychology and Behavior. 2001;4:711-722.
Suler J. The psychology of text relationships. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:19-50. New York. Elsevier Science.
Suler J. Cybertherapeutic theory and techniques. Barak A, editor. Psychological aspects of cyberspace: Theory, research, applications. 2008:102-128. New York. Cambridge University Press.
Suler J. (n.d.). The psychology of cyberspace. Retrieved June 29, 2014 from http://users.rider.edu/∼suler/psycyber/psycyber.html.
Sullivan G, Craske MG, Sherbourne C, Edlund MJ, Rose RD, Golinelli D, Roy-Byrne PP. Design of the Coordinated Anxiety Learning and Management study: Innovations in collaborative care for anxiety disorders. General Hospital Psychiatry. 2007;29:379-387. [pmid: 17888803].
Sunderland M, Wong N, Hilvert-Bruce Z, Andrews G. Investigating trajectories of change in psychological distress amongst patients with depression and generalised anxiety disorder treated with Internet cognitive behavioural therapy. Behaviour Research and Therapy. 2012;50:374-380. [pmid: 22498311].
Svensson M, Lagerros YT. Motivational technologies to promote weight loss–internet to gadgets. Patient Education and Counseling. 2010;79:356-360. [pmid: 20378298].
Swan AJ, Tyssen EG. Enhancing treatment access: Evaluation of an Australian Web-based alcohol and drug counselling initiative. Drug and Alcohol Review. 2009;28:48-53. [pmid: 19320675].
Swartz LH, Noell JW, Schroeder SW, Ary DV. A randomised control study of a fully automated Internet based smoking cessation programme. Tobacco Control. 2006;15:7-12. [pmid: 16436397].
Tait A. Face-to-face and at a distance: The mediation of guidance and counselling through the new technologies. British Journal of Guidance and Counselling. 1999;27:113-122.
Takahashi Y, Satomura K, Miyagishima K, Nakahara T, Higashiyama A, Iwai K, Nakamura K. A new smoking cessation programme using the Internet. Tobacco Control. 1999;8:109-110. [pmid: 10465831].
Takahashi Y, Uchida C, Miyaki K, Sakai M, Shimbo T, Nakayama T. Potential benefits and harms of a peer support social network service on the Internet for people with depressive tendencies: Qualitative content analysis and social network analysis. Journal of Medical Internet Research. 2009;11:e29. [pmid: 19632979].
Tan L. Psychotherapy 2.0: MySpace blogging as self-therapy. American Journal of Psychotherapy. 2008;62:143-163. [pmid: 18605128].
Tannenbaum D, Spiranovic C. Severe, recurrent depression managed in a remote setting via the Internet: An example of remote care using the HealthSteps system. Taylor CB, editor. How to practice evidence-based psychiatry: Basic principles and case studies. 2010:275-286. Arlington, VA. American Psychiatric Publishing.
Tantam D, Blackmore C, van Deurzen E. eLearning and traditional “face-to-face” teaching: A comparative evaluation of methods in a psychotherapy training programme. International Journal of Psychotherapy. 2006;10:7-14.
Tárraga L, Boada M, Modinos G, Espinosa A, Diego S, Morera A, Becker JT. A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer's disease. Journal of Neurology, Neurosurgery and Psychiatry. 2006;77:1116-1121.
Tasker AP, Gibson L, Franklin V, Gregor P, Greene S. What is the frequency of symptomatic mild hypoglycemia in type 1 diabetes in the young? Assessment by novel mobile phone technology and computer-based interviewing. Pediatric Diabetes. 2007;8:15-20. [pmid: 17341287].
Tate DF. A series of studies examining Internet treatment of obesity to inform Internet interventions for substance use and misuse. Substance Use & Misuse. 2011;46:57-65. [pmid: 21190406].
Tate DF, Finkelstein EA, Khavjou O, Gustafson A. Cost-effectiveness of Internet interventions: Review and recommendations. Annals of Behavioral Medicine. 2009;38:40-45. [pmid: 19834778].
Tate DF, Jackvony EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: A randomized trial. JAMA: Journal of the American Medical Association. 2003;289:1833-1836. [pmid: 12684363].
Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Archives of Internal Medicine. 2006;166:1620-1625. [pmid: 16908795].
Tate DF, Wing RR, Winett RA. Using Internet-based technology to deliver a behavioral weight loss program. JAMA: Journal of the American Medical Association. 2001;285:1172-1177. [pmid: 11231746].
Tate DF, Zabinski MF. Computer and Internet applications for psychological treatment: Update for clinicians. Journal of Clinical Psychology. 2004;60:209-220. [pmid: 14724928].
Taualii M, Bush N, Bowen DJ, Forquera R. Adaptation of a smoking cessation and prevention Website for urban American Indian/Alaska Native youth. Journal of Cancer Education. 2010;25:23-31. [pmid: 20082169].
Taylor CB, Bryson S, Luce KH, Cunning D, Doyle AC, Abascal LB, Wilfley DE. Prevention of eating disorders in at-risk college-age women. Archives of General Psychiatry. 2006;63:881-888. [pmid: 16894064].
Taylor CB, Jobson KO, Winzelberg A, Abascal L. The use of the Internet to provide evidence-based integrated treatment programs for mental health. Psychiatric Annals. 2002;32:671-677.
Taylor CB, Jones M. Internet-based prevention and treatment of obesity and body dissatisfaction. Latner JD, Wilson GT, editors. Self-help approaches for obesity and eating disorders: Research and practice. 2007:141-165. New York. Guilford Press.
Taylor CB, Luce KH. Computer- and Internet-based psychotherapy interventions. Current Directions in Psychological Science. 2003;12:18-22.
Technology-based interventions for substance use and related issues: Translated abstracts. Substance Use & Misuse. 2011;46:114-127. [pmid: 21609155].
Tenkku LE, Mengel MB, Nicholson RA, Hile MG, Morris DS, Salas J. A Web-based intervention to reduce alcohol-exposed pregnancies in the community. Health Education & Behavior. 2011;38:563-573. [pmid: 21471438].
Te Poel F, Bolman C, Reubsaet A, de Vries H. Efficacy of a single computer-tailored e-mail for smoking cessation: Results after 6 months. Health Education Research. 2009;24:930-940. [pmid: 19574405].
Terry NP. The legal implications of e-therapy. Hsiung RC, editor. E-therapy: Case studies, guiding principles, and the clinical potential of the Internet. 2002:166-193. New York. W. W. Norton & Co.
Teufel M, Schaffeler N, de Zwaan M, Graap H, Zipfel S, Giel KE. Internet use among patients with psychosomatic disorders: What are the health-related demands and needs?. Journal of Health Psychology. 2011;16:1120-1126. [pmid: 21459918].
Thara R. Using mobile telepsychiatry to close the mental health gap. Current Psychiatry Reports. 2012;14:167-168. [pmid: 22467357].
The California Telemedicine & eHealth Center. 2006. Telemedicine reimbursement handbook. Sacramento, CA. The California Telemedicine & eHealth Center.
The National Association of State Alcohol and Drug Abuse Directors. 2009. Telehealth in state substance use disorder (SUD) services. Washington DC. The National Association of State Alcohol and Drug Abuse Directors.
Thompson A. Using social networks and implications for the mental health. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:39-46. Springfield, IL. Charles C Thomas Publisher.
Thompson BM. 2010. FDA regulation of mobile health. Mobihealthnews 2010 report. Boston. MobiHealthNews.com.
Thompson D, Baranowski J, Cullen K, Baranowski T. Development of a theory-based Internet program promoting maintenance of diet and physical activity change to 8-year-old African American girls. Computers and Education. 2007;48:446-459.
Thorndike FP. Commentary: Interest in Internet interventions—An infant sleep program as illustration. Journal of Pediatric Psychology. 2009;34:470-473. [pmid: 19451170].
Thorp SR, Fidler J, Moreno L, Floto E, Agha Z. Lessons learned from studies of psychotherapy for posttraumatic stress disorder via video teleconferencing. Psychological Services. 2012;9:197-199. [pmid: 22662733].
Tierney S. The dangers and draw of online communication: Pro-anorexia Websites and their implications for users, practitioners, and researchers. Eating Disorders: The Journal of Treatment and Prevention. 2006;14:181-190.
Tillfors M, Carlbring P, Furmark T, Lewenhaupt S, Spak M, Eriksson A, Andersson G. Treating university students with social phobia and public speaking fears: Internet delivered self-help with or without live group exposure sessions. Depression and Anxiety. 2008;25:708-717. [pmid: 18729147].
Titov N. Status of computerized cognitive behavioural therapy for adults. Australian and New Zealand Journal of Psychiatry. 2007;41:95-114. [pmid: 17464688].
Titov N, Andrews G, Choi I, Schwencke G, Johnston L. Randomized controlled trial of Web-based treatment of social phobia without clinician guidance. Australian and New Zealand Journal of Psychiatry. 2009;43:913-919.
Titov N, Andrews G, Choi I, Schwencke G, Mahoney A. Shyness 3: Randomized controlled trial of guided versus unguided Internet-based CBT for social phobia. Australian and New Zealand Journal of Psychiatry. 2008;42:1030-1040. [pmid: 19016091].
Titov N, Andrews G, Davies M, McIntyre K, Robinson E, Solley K. Internet treatment for depression: A randomized controlled trial comparing clinician vs. technician assistance. PLOS ONE. 2010;5:e10939. [pmid: 20544030].
Titov N, Andrews G, Johnston L, Robinson E, Spence J. Transdiagnostic Internet treatment for anxiety disorders: A randomized controlled trial. Behaviour Research and Therapy. 2010;48:890-899. [pmid: 20561606].
Titov N, Andrews G, Johnston L, Schwencke G, Choi I. Shyness programme: Longer term benefits, cost-effectiveness, and acceptability. Australian and New Zealand Journal of Psychiatry. 2009;43:36-44. [pmid: 19085526].
Titov N, Andrews G, Robinson E, Schwencke G, Johnston L, Solley K. Clinician-assisted Internet-based treatment is effective for generalized anxiety disorder: Randomized controlled trial. Australian and New Zealand Journal of Psychiatry. 2009;43:905-912.
Titov N, Andrews G, Schwencke G. Shyness 2: Treating social phobia online: Replication and extension. Australian and New Zealand Journal of Psychiatry. 2008;42:595-605. [pmid: 18612863].
Titov N, Andrews G, Schwencke G, Drobny J, Einstein D. Shyness 1: Distance treatment of social phobia over the Internet. Australian and New Zealand Journal of Psychiatry. 2008;42:585-594. [pmid: 18612862].
Titov N, Andrews G, Schwencke G, Solley K, Johnston L, Robinson E. An RCT comparing effect of two types of support on severity of symptoms for people completing Internet-based cognitive behaviour therapy for social phobia. Australian and New Zealand Journal of Psychiatry. 2009;43:920-926.
Titov N, Dear BF, Schwencke G, Andrews G, Johnston L, Craske MG, McEvoy P. Transdiagnostic Internet treatment for anxiety and depression: A randomised controlled trial. Behaviour Research and Therapy. 2011;49(8):441-452. [pmid: 21679925].
Todd NJ, Jones SH, Lobban FA. “Recovery” in bipolar disorder: How can service users be supported through a self-management intervention? A qualitative focus group study. Journal of Mental Health. 2012;21:114-126. [pmid: 22142324].
Todd NJ, Jones SH, Lobban FA. What do service users with bipolar disorder want from a Web-based self-management intervention? A qualitative focus group study. Clinical Psychology & Psychotherapy. 2012;20(6):531-43. [pmid: 22715161].
Todder D, Matar M, Kaplan Z. Acute-phase trauma intervention using a videoconference link circumvents compromised access to expert trauma care. Telemedicine and e-Health. 2007;13:65-67. [pmid: 17309357].
Toll BA, Sobell LC, D'Arienzo J, Sobell MB, Eickleberry-Goldsmith L, Toll HJ. What do Internet-based alcohol treatment Websites offer?. CyberPsychology and Behavior. 2003;6:581-584. [pmid: 14763453].
Tomek L, Lamberti JS. Using telemedicine to coordinate inpatient and outpatient psychiatric care. Psychiatric Services. 2012;63:94. [pmid: 22227768].
Topolovec-Vranic J, Cullen N, Michalak A, Ouchterlony D, Bhalerao S, Masanic C, Cusimano MD. Evaluation of an online cognitive behavioural therapy program by patients with traumatic brain injury and depression. Brain Injury. 2010;24:762-772. [pmid: 20370383].
Toronto E. Time out of mind: Dissociation in the virtual world. Psychoanalytic Psychology. 2009;26:117-133.
Tossmann HP, Jonas B, Tensil MD, Lang P, Strüber E. A controlled trial of an Internet-based intervention program for cannabis users. Cyberpsychology, Behavior, and Social Networking. 2011;14:673-679.
Trautmann E, Kröner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. Behavioural and Cognitive Psychotherapy. 2008;36:241-245.
Trautmann E, Kröner-Herwig B. A randomized controlled trial of Internet-based self-help training for recurrent headache in childhood and adolescence. Behaviour Research and Therapy. 2010;48:28-37. [pmid: 19782343].
Treatment Research Institute. 2010. Integrating appropriate services for substance use conditions in health care settings: An issue brief on lessons learned and challenges ahead. forum on integration: Collaborative for states. Philadelphia. Author.
Trepal H, Haberstroh S, Duffey T, Evans M. Considerations and strategies for teaching online counseling skills: Establishing relationships in cyberspace. Counselor Education and Supervision. 2007;46:266-279.
Trudeau KJ, Quinonez L. Technology (A Web-based substance use prevention program is targeting youths in the particularly vulnerable 11-to-14 age group). Addiction Professional. 2008;6:42-43.
Tsai HH, Tsai YF. Changes in depressive symptoms, social support, and loneliness over 1 year after a minimum 3-month videoconference program for older nursing home residents. Journal of Medical Internet Research. 2011;13:e93. [pmid: 22086660].
Tsan JY, Day SX. Personality and gender as predictors of online counseling use. Journal of Technology in Human Services. 2007;25:39-55.
Tse MM, Choi KC, Leung RS. E-health for older people: The use of technology in health promotion. Cyberpsychology & Behavior. 2008;11:475-479. [pmid: 18721097].
Tucker JA, Foushee HR, Black BC. Behavioral economic analysis of natural resolution of drinking problems using IVR self-monitoring. Experimental and Clinical Psychopharmacology. 2008;16:332-340. [pmid: 18729688].
Tucker JA, Foushee HR, Black BC, Roth DL. Agreement between prospective interactive voice response self-monitoring and structured retrospective reports of drinking and contextual variables during natural resolution attempts. Journal of Studies on Alcohol and Drugs. 2007;68:538-542. [pmid: 17568958].
Tunick R, Mednick L. Commentary: Electronic communication in the pediatric setting-Dilemmas associated with patients' blogs. Journal of Pediatric Psychology. 2009;34:585-587. [pmid: 18701561].
Tunstall N, Prince M, Mann A. Concurrent validity of a telephone-administered version of the Gospel Oak instrument (including the SHORT-CARE). International Journal of Geriatric Psychiatry. 1997;12:1035-1038. [pmid: 9395936].
Turner JW. Telepsychiatry as a case study of presence: Do you know what you are missing?. Journal of Computer Mediated Communication. 2001;6(4).
Turvey CL, Willyard D, Hickman DH, Klein DM, Kukoyi O. Telehealth screen for depression in a chronic illness care management program. Telemedicine Journal and e-Health. 2007;13:51-56. [pmid: 17309355].
Tutty S, Spangler DL, Poppleton LE, Ludman EJ, Simon GE. Evaluating the effectiveness of cognitive-behavioral teletherapy in depressed adults. Behavior Therapy. 2010;41:229-236. [pmid: 20412887].
Twohig MP, Crosby JM. Acceptance and commitment therapy as a treatment for problematic Internet pornography viewing. Behavior Therapy. 2010;41:285-295. [pmid: 20569778].
Tzelepis F, Paul CL, Walsh RA, McElduff P, Knight J. Proactive telephone counseling for smoking cessation: Meta-analyses by recruitment channel and methodological quality. Journal of the National Cancer Institute. 2011;103:922-941. [pmid: 21666098].
Ulzen T, Williamson L, Foster P, Parris-Barnes K. The evolution of a community-based telepsychiatry program in rural Alabama: Lessons learned-A brief report. Community Mental Health Journal. 2012;49(1):101-105. [pmid: 22322325].
United Nations Office of Drugs and Crimes. 2003. Internet: Using the Internet for drug abuse prevention. Vienna. Author.
Usdan SL, Schumacher JE, Bernhardt JM. Impaired driving behaviors among college students: A comparison of Web-based daily assessment and retrospective timeline followback. Journal of Alcohol and Drug Education. 2004;48:34-50.
U.S. Department of Health and Human Services. 2006. HIPAA security guidance. Washington DC. Author.
U.S. Food and Drug Administration. 2014. Examples of mobile apps for which the FDA will exercise enforcement discretion. Silver Spring MD. Author.
U.S. Food and Drug Administration Center for Devices and Radiological Health & Center for Biologics Evaluation and Research. 2013. Mobile medical applications: Guidance for industry and Food and Drug Administration staff. Silver Spring MD. Author.
U.S. Department of Veterans Affairs & Patient Care Services. 2012. Medication use crisis. Washington DC. Author.
Vaca FE, Winn D, Anderson CL, Kim D, Arcila M. Six-month follow-up of computerized alcohol screening, brief intervention, and referral to treatment in the emergency department. Substance Abuse. 2011;32:144-152. [pmid: 21660874].
Vaccaro N, Lambie GW. Computer-based counselor-in-training supervision: Ethical and practical implications for counselor educators and supervisors. Counselor Education and Supervision. 2007;47:46-57.
Välimäki M, Hätönen H, Lahti M, Kuosmanen L, Adams CE. Information and communication technology in patient education and support for people with schizophrenia. Cochrane Database of Systematic Reviews. 2012;10. CD007198.
Vallejo MA, Jordan CM, Diaz MI, Comeche MI, Ortega J. Psychological assessment via the Internet: A reliability and validity study of online (vs. paper-and-pencil) versions of the General Health Questionnaire-28 (GHQ-28) and the Symptoms Check-Lis-90-Revised (SCL-90-R). Journal of Medical Internet Research. 2007;9:e2. [pmid: 17478411].
Vallejo MA, Jordan CM, Mananes G, Andres A, Comeche MI, Diaz MI. Clinical psychology offers in the internet in Spain. Computers in Human Behavior. 2007;23:2133-2143.
Van Ameringen M, Mancini C, Simpson W, Patterson B. Potential use of Internet-based screening for anxiety disorders: A pilot study. Depression and Anxiety. 2010;27:1006-1010. [pmid: 20721902].
van Bastelaar KM, Pouwer F, Cuijpers P, Riper H, Snoek FJ. Web-based depression treatment for type 1 and type 2 diabetic patients: A randomized, controlled trial. Diabetes Care. 2011;34:320-325. [pmid: 21216855].
Van Bockstaele B, Verschuere B, Koster EHW, Tibboel H, De Houwer J, Crombez G. Effects of attention training on self-reported, implicit, physiological and behavioural measures of spider fear. Journal of Behavior Therapy and Experimental Psychiatry. 2011;42:211-218. [pmid: 21315884].
Van De Belt TH, Engelen LJ, Berben SA, Schoonhoven. Definition of health 2.0 and medicine 2.0: A systematic review. Journal of Medical Internet Research. 2010;12:e18. [pmid: 20542857].
VanDeMark NR, Burrell NR, LaMendola WF, Hoich CA, Berg NP, Medina E. An exploratory study of engagement in a technology-supported substance abuse intervention. Substance Abuse Treatment, Prevention, and Policy. 2010;5:10.
van den Berg MH, Schoones JW, Vliet Vlieland TP. Internet-based physical activity interventions: A systematic review of the literature. Journal of Medical Internet Research. 2007;9:e26. [pmid: 17942388].
VandenBos GR, Williams S. The Internet versus the telephone: What is telehealth anyway?. Professional Psychology: Research and Practice. 2000;31:490-492.
van der Houwen K, Schut H, van den Bout J, Stroebe M, Stroebe W. The efficacy of a brief Internet-based self-help intervention for the bereaved. Behaviour Research and Therapy. 2010;48:359-367. [pmid: 20070953].
van der Mark M, Jonasson J, Svensson M, Linne Y, Rossner S, Lagerros YT. Older members perform better in an Internet-based behavioral weight loss program compared to younger members. Obesity Facts. 2009;2:74-79. [pmid: 20054209].
van der Zanden RA, Speetjens PA, Arntz KS, Onrust SA. Online group course for parents with mental illness: Development and pilot study. Journal of Medical Internet Research. 2010;12:e50. [pmid: 21169178].
Van Diest SL, Van Lankveld JJ, Leusink PM, Slob AK, Gijs L. Sex therapy through the Internet for men with sexual dysfunctions: A pilot study. Journal of Sex and Marital Therapy. 2007;33:115-133. [pmid: 17365513].
van Lankveld JJ, Leusink P, Van Diest S, Gijs L, Slob AK. Internet-based brief sex therapy for heterosexual men with sexual dysfunctions: A randomized controlled pilot trial. Journal of Sexual Medicine. 2009;6:2224-2236. [pmid: 19493295].
van Straten A, Cuijpers P, Smits N. Effectiveness of a Web-based self-help intervention for symptoms of depression, anxiety, and stress: Randomized controlled trial. Journal of Medical Internet Research. 2008;10:e7. [pmid: 18364344].
Van't Hof E, Cuijpers P, Stein DJ. Self-help and Internet-guided interventions in depression and anxiety disorders: A systematic review of meta-analyses. CNS Spectrums. 2009;14:34-40. [pmid: 19238128].
Van 't Riet J, Crutzen R, de Vries H. Investigating predictors of visiting, using, and revisiting an online health-communication program: A longitudinal study. Journal of Medical Internet Research. 2010;12:e37. [pmid: 20813716].
van Uden-Kraan FC, Drossaert HC, Taal E, Seydel RE, van de Laar AM. Self-reported differences in empowerment between lurkers and posters in online patient support groups. Journal of Medical Internet Research. 2008;10:e18. [pmid: 18653442].
Van Vliet H, Andrews G. Internet-based course for the management of stress for junior high schools. Australian and New Zealand Journal of Psychiatry. 2009;43:305-309. [pmid: 19296285].
Van Voorhees BW, Fogel J, Pomper BE, Marko M, Reid N, Watson N, Domanico R. Adolescent dose and ratings of an Internet-based depression prevention program: A randomized trial of primary care physician brief advice versus a motivational interview. Journal of Cognitive and Behavioral Psychotherapies. 2009;9:1-19. [pmid: 20694059].
Van Voorhees BW, Fogel J, Reinecke MA, Gladstone T, Stuart S, Gollan J, Bell C. Randomized clinical trial of an Internet-based depression prevention program for adolescents (Project CATCH-IT) in primary care: 12-week outcomes. Journal of Developmental and Behavioral Pediatrics. 2009;30:23-37. [pmid: 19194326].
Van Voorhees BW, Vanderplough-Booth K, Fogel J, Gladstone T, Bell C, Stuart S, Rainecke MA. Integrative Internet-based depression prevention for adolescents: A randomized clinical trial in primary care for vulnerability and protective factors. Journal of the Canadian Academy of Child and Adolescent Psychiatry/Journal de l'Academie Canadienne de Psychiatrie de L'enfant et de L'adolescent. 2008;17:184-196.
Van Vugt HC, Konijn EA, Hoorn JF, Veldhuis J. When too heavy is just fine: Creating trustworthy e-health advisors. International Journal of Human–Computer Studies. 2009;67:571-583.
van Wynsberghe A, Gastmans C. Telepsychiatry and the meaning of in-person contact: A preliminary ethical appraisal. Medicine, Health Care, and Philosophy. 2009;12:469-476.
Verheyen C, Goritz AS. Plain texts as an online mood-induction procedure. Social Psychology. 2009;40:6-15.
Vernmark K, Lenndin J, Bjarehed J, Carlsson M, Karlsson J, Oberg J, Andersson G. Internet administered guided self-help versus individualized e-mail therapy: A randomized trial of two versions of CBT for major depression. Behaviour Research and Therapy. 2010;48:368-376. [pmid: 20152960].
Vernon ML. A review of computer-based alcohol problem services designed for the general public. Journal of Substance Abuse Treatment. 2010;38:203-211. [pmid: 20015607].
Vesmarovich S, Hauber RP, Jones M. Using telecommunication technologies to change the world for people with disabilities related to catastrophic neurological impairment. CyberPsychology and Behavior. 2000;3:925-928.
Vilella A, Bayas JM, Diaz MT, Guinovart C, Diez C, Simo D, Cerezo J. The role of mobile phones in improving vaccination rates in travelers. Preventive Medicine. 2004;38:503-509. [pmid: 15020186].
Villani D, Riva G. Does interactive media enhance the management of stress? Suggestions from a controlled study. Cyberpsychology, Behavior and Social Networking. 2012;15:24-30.
Vincent N, Lewycky S. Logging on for better sleep: RCT of the effectiveness of online treatment for insomnia. Sleep: Journal of Sleep and Sleep Disorders Research. 2009;32:807-815.
Vogel PA, Launes G, Moen EM, Solem S, Hansen B, Haland AT, Himle JL. Videoconference- and cell phone-based cognitive-behavioral therapy of obsessive–compulsive disorder: A case series. Journal of Anxiety Disorders. 2012;26:158-164. [pmid: 22119331].
Vogl L, Teesson M, Andrews G, Bird K, Steadman B, Dillon P. A computerized harm minimization prevention program for alcohol misuse and related harms: Randomized controlled trial. Addiction. 2009;104:564-575. [pmid: 19335655].
Wade SL, Carey J, Wolfe CR. An online family intervention to reduce parental distress following pediatric brain injury. Journal of Consulting and Clinical Psychology. 2006;74:445-454. [pmid: 16822102].
Wade SL, Carey J, Wolfe CR. The efficacy of an online cognitive-behavioral family intervention in improving child behavior and social competence following pediatric brain injury. Rehabilitation Psychology. 2006;51:179-189.
Wade SL, Oberjohn K, Burkhardt A, Greenberg I. Feasibility and preliminary efficacy of a Web-based parenting skills program for young children with traumatic brain injury. Journal of Head Trauma Rehabilitation. 2009;24:239-247. [pmid: 19625863].
Wade SL, Walz NC, Carey JC, Williams KM. Brief report: Description of feasibility and satisfaction findings from an innovative online family problem-solving intervention for adolescents following traumatic brain injury. Journal of Pediatric Psychology. 2009;34:517-522. [pmid: 18667477].
Wade SL, Wolfe C, Pestian JP. A Web-based family problem-solving intervention for families of children with traumatic brain injury. Behavior Research Methods, Instruments and Computers. 2004;36:261-269.
Wade SL, Wolfe CR, Brown TM, Pestian JP. Can a Web-based family problem-solving intervention work for children with traumatic brain injury?. Rehabilitation Psychology. 2005;50:337-345.
Wade SL, Wolfe C, Brown TM, Pestian JP. Putting the pieces together: Preliminary efficacy of a Web-based family intervention for children with traumatic brain injury. Journal of Pediatric Psychology. 2005;30:437-442. [pmid: 15944171].
Wagner B, Knaevelsrud C, Maercker A. Internet-based treatment for complicated grief: Concepts and case study. Journal of Loss and Trauma. 2005;10:409-432.
Wagner B, Knaevelsrud C, Maercker A. Internet-based cognitive–behavioral therapy for complicated grief: A randomized controlled trial. Death Studies. 2006;30:429-453. [pmid: 16610157].
Wagner B, Knaevelsrud C, Maercker A. Post-traumatic growth and optimism as outcomes of an Internet-based intervention for complicated grief. Cognitive Behaviour Therapy. 2007;36:156-161. [pmid: 17852173].
Wagner B, Maercker A. A 1.5-year follow-up of an Internet-based intervention for complicated grief. Journal of Traumatic Stress. 2007;20:625-629. [pmid: 17721955].
Wagner B, Schulz W, Knaevelsrud C. Efficacy of an Internet-based intervention for posttraumatic stress disorder in Iraq: A pilot study. Psychiatry Research. 2012;195:85-88. [pmid: 21813187].
Wald HS, Dube CE, Anthony DC. Untangling the Web––The impact of Internet use on health care and the physician–patient relationship. Patient Education and Counseling. 2007;68:218-224. [pmid: 17920226].
Walker BM, Harper J, Lloyd C, Caputi P. Methodologies for the exploration of computer and technology transference. Computers in Human Behavior. 2003;19:523-535.
Walker DD, Roffman RA, Picciano JF, Stephens RS. The check-up: In-person, computerized, and telephone adaptations of motivational enhancement treatment to elicit voluntary participation by the contemplator. Substance Abuse Treatment, Prevention, and Policy. 2007;2:2.
Wall AF. Evaluating a health education Web site: The case of AlcoholEdu. NASPA Journal. 2007;44:692-714.
Wallace P, Linke S, Murray E, McCambridge J, Thompson S. A randomized controlled trial of an interactive Web-based intervention for reducing alcohol consumption. Journal of Telemedicine and Telecare. 2006;12:52-54. [pmid: 16884581].
Waller R, Gilbody S. Barriers to the uptake of computerized cognitive behavioural therapy: A systematic review of the quantitative and qualitative evidence. Psychological Medicine. 2009;39:705-712. [pmid: 18812006].
Walters ST, Miller E, Chiauzzi E. Wired for wellness: E-interventions for addressing college drinking. Journal of Substance Abuse Treatment. 2005;29:139-145. [pmid: 16135342].
Walters ST, Vader AM, Harris TR. A controlled trial of Web-based feedback for heavy drinking college students. Prevention Science. 2007;8:83-88. [pmid: 17136461].
Walters ST, Wright JA, Shegog R. A review of computer and Internet-based interventions for smoking behavior. Addictive Behaviors. 2006;31:264-277. [pmid: 15950392].
Wang J, Etter JF. Administering an effective health intervention for smoking cessation online: The international users of Stop-Tabac. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2004;39:962-968.
Wang PS, Simon GE, Avorn J, Azocar F, Ludman EJ, McCulloch J, Kessler RC. Telephone screening, outreach, and care management for depressed workers and impact on clinical and work productivity outcomes: A randomized controlled trial. JAMA. 2007;298:1401-1411. [pmid: 17895456].
Wangberg SC, Gammon D, Spitznogle K. In the eyes of the beholder: Exploring psychologists' attitudes towards and use of e-therapy in Norway. CyberPsychology and Behavior. 2007;10:418-423. [pmid: 17594266].
Wanner M, Martin-Diener E, Braun-Fahrlander C, Bauer G, Martin WB. Effectiveness of active-online, an individually tailored physical activity intervention, in a real-life setting: Randomized controlled trial. Journal of Medical Internet Research. 2009;11:e23. [pmid: 19666456].
Wantland DJ, Portillo CJ, Holzemer WL, Slaughter R, McGhee EM. The effectiveness of Web-based vs. non-web-based interventions: A meta-analysis of behavioral change outcomes. Journal of Medical Internet Research. 2004;6:e40. [pmid: 15631964].
Wardell TL. Electronic resources to support evidence-based practice in the home health care setting. Home Health Care Management and Practice. 2005;17:333-339.
Warmerdam L, van Straten A, Jongsma J, Twisk J, Cuijpers P. Online cognitive behavioral therapy and problem-solving therapy for depressive symptoms: Exploring mechanisms of change. Journal of Behavior Therapy and Experimental Psychiatry. 2010;41:64-70. [pmid: 19913781].
Warmerdam L, van Straten A, Twisk J, Riper H, Cuijpers P. Internet-based treatment for adults with depressive symptoms: Randomized controlled trial. Journal of Medical Internet Research. 2008;10:e44. [pmid: 19033149].
Wasko NH. Internet technology makes clinical data systems technically and economically practical: Are they politically feasible?. Journal of Technology in Human Services. 2001;18:41-62.
Watkins DC, Smith LC, Kerber K, Kuebler J, Himle JA. Email reminders as a self-management tool in depression: A needs assessment to determine patients' interests and preferences. Journal of Telemedicine and Telecare. 2011;17:378-381. [pmid: 21933895].
Watson A, Bickmore T, Cange A, Kulshreshtha A, Kvedar J. An Internet-based virtual coach to promote physical activity adherence in overweight adults: Randomized controlled trial. Journal of Medical Internet Research. 2012;14:e1. [pmid: 22281837].
Webb TL. Commentary on Shahab & McEwen (2009): Understanding and preventing attrition in online smoking cessation interventions: A self-regulatory perspective. Addiction. 2009;104:1805-1806. [pmid: 19832784].
Webb TL, Joseph J, Yardley L, Michie S. Using the Internet to promote health behavior change: A systematic review and meta-analysis of the impact of theoretical basis, use of behavior change techniques, and mode of delivery on efficacy. Journal of Medical Internet Research. 2010;12:e4. [pmid: 20164043].
Webber KH, Tate DF, Bowling JM. A randomized comparison of two motivationally enhanced Internet behavioral weight loss programs. Behaviour Research and Therapy. 2008;46:1090-1095. [pmid: 18675402].
Webber KH, Tate DF, Ward DS, Bowling JM. Motivation and its relationship to adherence to self-monitoring and weight loss in a 16-week Internet behavioral weight loss intervention. Journal of Nutrition Education and Behavior. 2010;42:161-167. [pmid: 20138583].
Wei J, Hollin I, Kachnowski S. A review of the use of mobile phone text messaging in clinical and healthy behaviour interventions. Journal of Telemedicine and Telecare. 2011;17:41-48. [pmid: 21097565].
Weinberg H. Group process and group phenomena on the Internet. International Journal of Group Psychotherapy. 2001;51:361-378. [pmid: 11447785].
Weingardt KR. Evaluation. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:247-265. New York. Routledge/Taylor & Francis Group.
Weingardt KR, Cucciare MA, Bellotti C, Lai WP. A randomized trial comparing two models of Web-based training in cognitive–behavioral therapy for substance abuse counselors. Journal of Substance Abuse Treatment. 2009;37:219-227. [pmid: 19339136].
Weingardt KR, Lysell KM. 2007. Session 125 My recovery plan: Using my HealtheVet to support veterans with mental health and substance use disorders. [Powerpoint presentation]. Washington DC. U.S. Department of Veterans Affairs.
Weingardt KR, Lysell KM. 2010. Mental health–My recovery plan VA 2010 eHealth University. Washington DC. U.S. Department of Veterans Affairs.
Weingardt KR, Villafranca SW, Levin C. Technology-based training in cognitive behavioral therapy for substance abuse counselors. Substance Abuse. 2006;27:19-25. [pmid: 17135177].
Weinstein PK. A review of weight loss programs delivered via the Internet. Journal of Cardiovascular Nursing. 2006;21:251-258. [pmid: 16823276].
Weiser M. The computer for the 21st century. Scientific American. 1991;265:3-11.
Weiss R. Treating sex addiction. Coombs RH, editor. Handbook of addictive disorders: A practical guide to diagnosis and treatment. 2004:233-272. Hoboken, NJ. John Wiley & Sons Inc.
Weitzel JA, Bernhardt JM, Usdan S, Mays D, Glanz K. Using wireless handheld computers and tailored text messaging to reduce negative consequences of drinking alcohol. Journal of Studies on Alcohol and Drugs. 2007;68:534-537. [pmid: 17568957].
Welfel ER. E-therapy: A question of ethics. Behavioral Health Management. 2003;23:17-19.
Welfel ER, Heinlen K. Ethics in technology and mental health. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician's guide. 2010:267-290. New York. Routledge/Taylor & Francis Group.
Wen KY, Gustafson DH, Hawkins RP, Brennan PF, Dinauer S, Johnson PR, Siegler T. Developing and validating a model to predict the success of an IHCS implementation: The Readiness for Implementation Model. Journal of the American Medical Informatics Association. 2010;17:707-713. [pmid: 20962135].
West R, Gilsenan A, Coste F, Zhou X, Brouard R, Nonnemaker J, Sullivan SD. The ATTEMPT cohort: A multi-national longitudinal study of predictors, patterns and consequences of smoking cessation; introduction and evaluation of Internet recruitment and data collection methods. Addiction. 2006;101:1352-1361. [pmid: 16911736].
Westphal A, Dingjan P, Attoe R. What can low and high technologies do for late-life mental disorders?. Current Opinion in Psychiatry. 2010;23:510-515. [pmid: 20717039].
Wetherell JL, Petkus AJ, Thorp SR, Stein MB, Chavira DA, Campbell-Sills L, Craske MG, Roy-Byrne P. Age differences in treatment response to a collaborative care intervention for anxiety disorders. British Journal of Psychiatry. 2013;203(1):65-72. [pmid: 23580378].
White A, Kavanagh D, Stallman H, Klein B, Kay-Lambkin F, Proudfoot J, Young R. Online alcohol interventions: A systematic review. Journal of Medical Internet Research. 2010;12:e62. [pmid: 21169175].
White H. Locating clinical boundaries in the World Wide Web. American Journal of Psychiatry. 2009;166:620-621. [pmid: 19411386].
White MA, Martin PD, Newton RL, Walden HM, York-Crowe EE, Gordon ST, Williamson DA. Mediators of weight loss in a family-based intervention presented over the Internet. Obesity Research. 2004;12:1050-1059. [pmid: 15292468].
Whitfield G, Hinshelwood R, Pashely A, Campsie L, Williams C. The impact of a novel computerized CBT CD-ROM (overcoming depression) offered to patients referred to clinical psychology. Behavioural and Cognitive Psychotherapy. 2006;34:1-11.
Whitlock J, Lader W, Conterio K. The Internet and self-injury: What psychotherapists should know. Journal of Clinical Psychology. 2007;63:1135-1143. [pmid: 17932984].
Whitlock JL, Powers JL, Eckenrode J. The virtual cutting edge: The Internet and adolescent self-injury. Developmental Psychology. 2006;42:407-417. [pmid: 16756433].
Whittaker R, McRobbie H, Bullen C, Borland R, Rodgers A, Gu Y. Mobile phone-based interventions for smoking cessation. Cochrane Database of Systematic Reviews. 2012;11. CD006611.
Whitten P, Buis L. Private payer reimbursement for telemedicine services in the United States. Telemedicine Journal and e-Health. 2007;13:15-23. [pmid: 17309350].
Whitten P, Zaylor C, Kingsley C. An analysis of telepsychiatry programs from an organizational perspective. CyberPsychology and Behavior. 2000;3:911-916.
Whittle J, Segal JB. What can the VA teach us about implementing proven advances into routine clinical practice?. Journal of General Internal Medicine. 2010;25:S77-S78.
Wiederhold BK, Gevirtz R, Wiederhold MD. Fear of flying: A case report using virtual reality therapy with physiological monitoring. CyberPsychology and Behavior. 1998;1:97-103.
Wiederhold BK, Wiederhold MD. A review of virtual reality as a psychotherapeutic tool. CyberPsychology and Behavior. 1998;1:45-52.
Wiers RW, Eberl C, Rinck M, Becker ES, Lindenmeyer J. Retraining automatic action tendencies changes alcoholic patients' approach bias for alcohol and improves treatment outcome. Psychological Science. 2011;22:490-497. [pmid: 21389338].
Wiersma JE, Titov N, Van Schaik DJ, van Oppen P, Beekman AT, Cuijpers P, Andrews GA. Treating chronic symptoms of depression in the virtual clinic: Findings on chronicity of depression in patients treated with Internet-based computerized cognitive behaviour therapy for depression. Psychotherapy and Psychosomatics. 2011;80:313-315. [pmid: 21720195].
Wilkinson N, Ang RP, Goh DH. Online video game therapy for mental health concerns: A review. International Journal of Social Psychiatry. 2008;54:370-382. [pmid: 18720897].
Williams J, Herman-Stahl M, Calvin SL, Pemberton M, Bradshaw M. Mediating mechanisms of a military Web-based alcohol intervention. Drug and Alcohol Dependence. 2009;100:248-257. [pmid: 19081206].
Williams R, Bambling M, King R, Abbott Q. In-session processes in online counselling with young people: An exploratory approach. Counselling and Psychotherapy Research. 2009;9:93-100.
Williamson DA, Davis Martin P, White MA, Newton R, Walden H, York-Crowe E, Ryan D. Efficacy of an Internet-based behavioral weight loss program for overweight adolescent African American girls. Eating and Weight Disorders. 2005;10:193-203. [pmid: 16277142].
Wilson GT, Zandberg LJ. Cognitive-behavioral guided self-help for eating disorders: effectiveness and scalability. Clinical Psychology Review. 2012;32:343-357. [pmid: 22504491].
Wilson JA, Wells MG. Telehealth and the deaf: A comparison study. Journal of Deaf Studies and Deaf Education. 2009;14:386-402. [pmid: 19398534].
Wilson JL, Peebles R, Hardy KK, Litt IF. Surfing for thinness: A pilot study of pro-eating disorder Web site usage in adolescents with eating disorders. Pediatrics. 2006;118:e1635-e1643. [pmid: 17142493].
Wims E, Titov N, Andrews G, Choi I. Clinician-assisted Internet-based treatment is effective for panic: A randomized controlled trial. Australian and New Zealand Journal of Psychiatry. 2010;44:599-607. [pmid: 20560847].
Winett RA, Tate DF, Anderson ES, Wojcik JR, Winett SG. Long-term weight gain prevention: A theoretically based Internet approach. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2005;41:629-641.
Winett RA, Tate DF, Anderson ES, Wojcik JR, Winett SG. Preventing weight gain with Internet programs. Watkins PL, Clum GA, editors. Handbook of self-help therapies. 2008:325-353. New York. Routledge/Taylor & Francis Group. Mahwah, NJ. Erlbaum.
Wing RR, Tate DF, Gorin AA, Raynor HA, Fava JL. A self-regulation program for maintenance of weight loss. New England Journal of Medicine. 2006;355:1563-1571. [pmid: 17035649].
Winker MA, Flanagin A, Chi-Lum B, White J, Andrews K, Kennett RL, Musacchio RA. Guidelines for medical and health information sites on the Internet: Principles governing AMA Web sites. JAMA. 2000;283:1600-1606. [pmid: 10735398].
Winzelberg AJ, Eppstein D, Eldredge KL, Wilfley D, Dasmahapatra R, Dev P, Taylor CB. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. Journal of Consulting and Clinical Psychology. 2000;68:346-350. [pmid: 10780136].
Wisdom JP, Ford JH II, McCarty D. The use of health information technology in publicly-funded U.S. substance abuse treatment agencies. Contemporary Drug Problems: An Interdisciplinary Quarterly. 2010;37:315-339.
Wise PH, Dowlatshahi DC, Farrant S, Fromson S, Meadows KA. Effect of computer-based learning on diabetes knowledge and control. Diabetes Care. 1986;9:504-508. [pmid: 3533475].
Witte TK, Gould MS, Harris Munfakh JL, Kleinman M, Joiner TE Jr., Kalafat J. Assessing suicide risk among callers to crisis hotlines: A confirmatory factor analysis. Journal of Clinical Psychology. 2010;66:941-964. [pmid: 20578186].
Wodarski JS. Preparing social services and public services professionals for meaningful roles in disaster services. Stress, Trauma and Crisis. 2004;7:209-222.
Wolf AW. Internet and video technology in psychotherapy supervision and training. Psychotherapy. 2011;48:179-181. [pmid: 21639661].
Wolf M, Bauer S. CMC for the enhancement of psychotherapy. Kelsey S, Amant KSt, editors. Handbook of research on computer mediated communication. 2008:602-618. Hershey, PA. Information Science Reference/IGI Global.
Wolf M, Chung CK, Kordy H. Inpatient treatment to online aftercare: E-mailing themes as a function of therapeutic outcomes. Psychotherapy Research. 2010;20:71-85. [pmid: 19821186].
Wolf M, Ebner-Priemer U, Schramm E, Domsalla M, Hautzinger M, Bohus M. Maximizing skills acquisition in dialectical behavioral therapy with a CD-ROM-based self-help program: Results from a pilot study. Psychopathology. 2011;44:133-135. [pmid: 21228618].
Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial Internet weight loss program. Obesity Research. 2004;12:1011-1018. [pmid: 15229342].
Wood JAV, Miller TW, Hargrove DS. Clinical supervision in rural settings: A telehealth model. Professional Psychology: Research and Practice. 2005;36:173-179.
Wood RTA, Griffiths MD. Online guidance, advice, and support for problem gamblers and concerned relatives and friends: An evaluation of the GamAid pilot service. British Journal of Guidance and Counselling. 2007;35:373-389.
Wood RTA, Wood SA. An evaluation of two United Kingdom online support forums designed to help people with gambling issues. Journal of Gambling Issues. 2009;23:5-30.
Woodford J, Farrand P, Bessant M, Williams C. Recruitment into a guided Internet based CBT (iCBT) intervention for depression: Lesson learnt from the failure of a prevalence recruitment strategy. Contemporary Clinical Trials. 2011;32:641-648. [pmid: 21570485].
Woodruff SI, Conway TL, Edwards CC, Elliott SP, Crittenden J. Evaluation of an Internet virtual world chat room for adolescent smoking cessation. Addictive Behaviors. 2007;32:1769-1786. [pmid: 17250972].
Woodruff SI, Edwards CC, Conway TL, Elliott SP. Pilot test of an Internet virtual world chat room for rural teen smokers. Journal of Adolescent Health. 2001;29:239-243. [pmid: 11587907].
Worrall JM, Fruzzetti AE. Improving peer supervisor ratings of therapist performance in dialectical behavior therapy: An Internet-based training system. Psychotherapy: Theory, Research, Practice, Training. 2009;46:476-479.
Wright B, Williams C, Partridge I. Re: Chronic fatigue syndrome. Irish Journal of Psychological Medicine. 2000;17:77.
Wright J. Online counselling: Learning from writing therapy. British Journal of Guidance and Counselling. 2002;30:285-298.
Wright J, Chung MC. Mastery or mystery? Therapeutic writing: A review of the literature. British Journal of Guidance and Counselling. 2001;29:277-291.
Wyn J, Cuervo H, Woodman D, Stokes H. 2005. Young people, well being and communication technologies. Melbourne, Australia. Youth Research Centre University of Melbourne.
Xu R, Mei G, Zhang G, Gao P, Judkins T, Cannizzaro M, Li J. A voice-based automated system for PTSD screening and monitoring. Studies in Health Technology and Informatics. 2012;173:552-558. [pmid: 22357057].
Yager J. E-mail as a therapeutic adjunct in the outpatient treatment of anorexia nervosa: Illustrative case material and discussion of the issues. International Journal of Eating Disorders. 2001;29:125-138. [pmid: 11429975].
Yager J. Using e-mail to support the outpatient treatment of anorexia nervosa. Hsiung RC, editor. E-therapy: Case studies, guiding principles, and the clinical potential of the Internet. 2002:39-68. New York. W. W. Norton & Co.
Yager Z, O'Dea JA. Prevention programs for body image and eating disorders on university campuses: A review of large, controlled interventions. Health Promotion International. 2008;23:173-189. [pmid: 18263883].
Yamagishi M, Kobayashi T, Kobayashi T, Nagami M, Shimazu A, Kageyama T. Effect of Web-based assertion training for stress management of Japanese nurses. Journal of Nursing Management. 2007;15:603-607. [pmid: 17688565].
Yamagishi M, Kobayashi T, Nakamura Y. Effects of Web-based career identity training for stress management among Japanese nurses: A randomized control trial. Journal of Occupational Health. 2008;50:191-193. [pmid: 18403870].
Yaphe J, Speyer C. Using email to enrich counselor training and supervision. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:194-205. Springfield, IL. Charles C Thomas Publisher.
Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: A randomized controlled evaluation. Health Promotion International. 2007;22:122-128. [pmid: 17355994].
Ybarra ML, Bull SS. Current trends in Internet- and cell phone-based HIV prevention and intervention programs. Current HIV/AIDS Reports. 2007;4:201-207. [pmid: 18366952].
Ybarra ML, Eaton WW. Internet-based mental health interventions. Mental Health Services Research. 2005;7:75-87. [pmid: 15974154].
Ybarra ML, Suman M. Help seeking behavior and the Internet: A national survey. International Journal of Medical Information. 2006;75:29-41.
Ye J, Rust G, Fry-Johnson Y, Strothers H. E-mail in patient–provider communication: A systematic review. Patient Education and Counseling. 2010;80:266-273. [pmid: 19914022].
Yeh CJ, Chang T, Chiang L, Drost CM, Spelliscy D, Carter RT, Chang Y. Development, content, process and outcome of an online peer supervision group for counselor trainees. Computers in Human Behavior. 2008;24:2889-2903.
Yellowlees PM. Clinical principles to guide the practice of e-therapy. Hsiung RC, editor. E-therapy: Case studies, guiding principles, and the clinical potential of the Internet. 2002:136-149. New York. W. W. Norton & Co.
Yellowlees PM, Burke MM, Marks SL, Hilty DM, Shore JH. Emergency telepsychiatry. Journal of Telemedicine and Telecare. 2008;14:277-281. [pmid: 18776070].
Yellowlees PM, Hilty DM, Marks SL, Neufeld J, Bourgeois JA. A retrospective analysis of a child and adolescent eMental Health program. Journal of the American Academy of Child and Adolescent Psychiatry. 2008;47:103-107. [pmid: 18174831].
Yellowlees PM, Holloway KM, Parish MB. Therapy in virtual environments-Clinical and ethical issues. Telemedicine and e-Health. 2012;18:558-564. [pmid: 22823138].
Yellowlees PM, Marks S. Problematic Internet use or Internet addiction?. Computers in Human Behavior. 2007;23:1447-1453.
Yellowlees PM, Nafiz N. The psychiatrist-patient relationship of the future: Anytime, anywhere?. Harvard Review of Psychiatry. 2010;18:96-102. [pmid: 20235774].
Yellowlees PM, Odor A, Parish MB, Iosif AM, Haught K, Hilty D. A feasibility study of the use of asynchronous telepsychiatry for psychiatric consultations. Psychiatric Services. 2010;61:838-840. [pmid: 20675845].
Young KS. Cognitive behavior therapy with Internet addicts: Treatment outcomes and implications. CyberPsychology and Behavior. 2007;10:671-679. [pmid: 17927535].
Young KS. Internet sex addiction risk factors, stages of development, and treatment. American Behavioral Scientist. 2008;52:21-37.
Young KS. Assessment and treatment of Internet addiction. Browne-Miller A, editor. The Praeger international collection on addictions 4 : Behavioral addictions from concept to compulsion. 2009:217-234. Santa Barbara, CA. Praeger/ABC–CLIO.
Young KS. Internet addiction: Diagnosis and treatment considerations. Journal of Contemporary Psychotherapy. 2009;39:241-246.
Young KS, Griffin-Shelley E, Cooper A, O'Mara J, Buchanan J. Online infidelity: A new dimension in couple relationships with implications for evaluation and treatment. Sexual Addiction and Compulsivity. 2000;7:59-74.
Young TL. Telepsychiatry's potential in schools. (Bringing psychiatric services to kids with phone and Internet technologies.). Behavioral Health Management. 2004;24:21-24.
Yuen EK, Goetter EM, Herbert JD, Forman EM. Challenges and opportunities in Internet-mediated telemental health. Professional Psychology: Research and Practice. 2012;43:1-8.
Zabinski MF, Celio AA, Wilfley DE, Taylor CB. Prevention of eating disorders and obesity via the Internet. Cognitive Behaviour Therapy. 2003;32:137-150. [pmid: 16291545].
Zabinski MF, Pung MA, Wilfley DE, Eppstein DL, Winzelberg AJ, Celio A, Taylor CB. Reducing risk factors for eating disorders: Targeting at-risk women with a computerized psychoeducational program. International Journal of Eating Disorders. 2001;29:401-408. [pmid: 11285577].
Zabinski MF, Wilfley DE, Calfas KJ, Winzelberg AJ, Taylor CB. An interactive psychoeducational intervention for women at risk of developing an eating disorder. Journal of Consulting and Clinical Psychology. 2004;72:914-919. [pmid: 15482051].
Zack JS. Technology of online counseling. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:93-121. New York. Elsevier Science.
Zack JS. How sturdy is that digital couch? Legal considerations for mental health professionals who deliver clinical services via the Internet. Journal of Technology in Human Services. 2008;26:333-359.
Zanjani F, Bush H, Oslin D. Telephone-based psychiatric referral–Care management intervention health outcomes. Telemedicine Journal and e-Health. 2010;16:543-550. [pmid: 20575721].
Zbikowski MS, Hapgood J, Smucker Barnwell S, McAfee T. Phone and Web-based tobacco cessation treatment: Real-world utilization patterns and outcomes for 11,000 tobacco users. Journal of Medical Internet Research. 2008;10:e41. [pmid: 19017583].
Zelvin EJ. Treating addictions in cyberspace. Journal of Social Work Practice in the Addictions. 2003;3:105-112.
Zelvin EJ. Partners and adult children of alcoholics in online treatment. Journal of Social Work Practice in the Addictions. 2006;6:181-185.
Zelvin E, Speyer CM. Online counseling skills, part I: Treatment strategies and skills for conducting counseling online. Kraus R, Zack JS, Stricker G, editors. Online counseling: A handbook for mental health professionals. 2004:163-180. New York. Elsevier Science.
Zetin M, Glenn T. Development of a computerized psychiatric diagnostic interview for use by mental health and primary care clinicians. CyberPsychology and Behavior. 1999;2:223-229. [pmid: 19178239].
Zetterqvist K, Maanmies J, Strom L, Andersson G. Randomized controlled trial of Internet-based stress management. Cognitive Behaviour Therapy. 2003;32:151-160. [pmid: 16291546].
Zhu SH, Stretch V, Balabanis M, Rosbrook B, Sadler G, Pierce JP. Telephone counseling for smoking cessation: Effects of single-session and multiple-session interventions. Journal of Consulting and Clinical Psychology. 1996;64:202-211. [pmid: 8907100].
Zizek S. What can psychoanalysis tell us about cyberspace?. Psychoanalytic Review. 2004;91:801-830. [pmid: 15841731].
Zuckerman E. Finding, evaluating, and incorporating Internet self-help resources into psychotherapy practice. Journal of Clinical Psychology. 2003;59:217-225. [pmid: 12552630].
Zur O, Williams MH, Lehavot K, Knapp S. Psychotherapist self-disclosure and transparency in the Internet age. Professional Psychology: Research and Practice. 2009;40:22-30.