# Links to Select Abstracts

aan het Rot M, Hogenelst K, Schoevers RA. Mood disorders in everyday life: A systematic review of experience sampling and ecological momentary assessment studies. Clinical Psychology Review. 2012;32:510-523. [pmid: 22721999].
Abbass A, Arthey S, Elliott J, Fedak T, Nowoweiski D, Markovski J, Nowoweiski S. Web-conference supervision for advanced psychotherapy training: A practical guide. Psychotherapy. 2011;48:109-118. [pmid: 21639654].
Almlov J, Carlbring P, Berger T, Cuijpers P, Andersson G. Therapist factors in Internet-delivered cognitive behavioural therapy for major depressive disorder. Cognitive Behaviour Therapy. 2009;38:247-254. [pmid: 19802751].
Amstadter AB, Broman-Fulks J, Zinzow H, Ruggiero KJ, Cercone J. Internet-based interventions for traumatic stress-related mental health problems: A review and suggestion for future research. Clinical Psychology Review. 2009;29:410-420. [pmid: 19403215].
Andersson G, Cuijpers P. Internet-based and other computerized psychological treatments for adult depression: A meta-analysis. Cognitive Behaviour Therapy. 2009;38:196-205. [pmid: 20183695].
Armfield NR, Gray LC, Smith AC. Clinical use of Skype: A review of the evidence base. Journal of Telemedicine and Telecare. 2012;18:125-127. [pmid: 22362829].
Atherton H, Sawmynaden P, Sheikh A, Majeed A, Car J. Email for clinical communication between patients/caregivers and healthcare professionals. Cochrane Database of Systematic Reviews. 2012;11. CD007978.
Backhaus A, Agha Z, Maglione ML, Repp A, Ross B, Zuest D, Thorp SR. Videoconferencing psychotherapy: A systematic review. Psychological Services. 2012;9:111-131. [pmid: 22662727].
Barlow JH, Ellard DR, Hainsworth JM, Jones FR, Fisher A. A review of self-management interventions for panic disorders, phobias and obsessive–compulsive disorders. Acta Psychiatrica Scandinavica. 2005;111:272-285. [pmid: 15740463].
Bickel WK, Marsch LA, Buchhalter AR, Badger GJ. Computerized behavior therapy for opioid-dependent outpatients: A randomized controlled trial. Experimental and Clinical Psychopharmacology. 2008;16:132-143. [pmid: 18489017].
Blankers M, Koeter MWJ, Schippers GM. Internet therapy versus Internet self-help versus no treatment for problematic alcohol use: A randomized controlled trial. Journal of Consulting and Clinical Psychology. 2011;79:330-341. [pmid: 21534652].
Brodey BB, Rosen CS, Brodey IS, Sheetz BM, Steinfeld RR, Gastfriend DR. Validation of the Addiction Severity Index (ASI) for Internet and automated telephone self-report administration. Journal of Substance Abuse Treatment. 2004;26:253-259. [pmid: 15182889].
Carey KB, Scott-Sheldon LA, Elliott JC, Bolles JR, Carey MP. Computer-delivered interventions to reduce college student drinking: A meta-analysis. Addiction. 2009;104:1807-1819. [pmid: 19744139].
Carroll KM, Ball SA, Martino S, Nich C, Babuscio TA, Nuro KF, Rounsaville BJ. Computer-assisted delivery of cognitive–behavioral therapy for addiction: A randomized trial of CBT4CBT. American Journal of Psychiatry. 2008;165:881-888. [pmid: 18450927].
Chen YF, Madan J, Welton N, Yahaya I, Aveyard P, Bauld L, Munafò MR. Effectiveness and cost-effectiveness of computer and other electronic aids for smoking cessation: A systematic review and network meta-analysis. Health Technology Assessment. 2012;16:iii-v.
Chiauzzi E, Green TC, Lord S, Thum C, Goldstein M. My Student Body: A high-risk drinking prevention Web site for college students. Journal of American College Health. 2005;53:263-274. [pmid: 15900990].
Craske MG, Rose RD, Lang A, Welch SS, Campbell-Sills L, Sullivan G, Roy-Byrne PP. Computer-assisted delivery of cognitive behavioral therapy for anxiety disorders in primary-care settings. Depression and Anxiety. 2009;26:235-242. [pmid: 19212970].
Cuijpers P, Marks IM, van Straten A, Cavanagh K, Gega L, Andersson G. Computer-aided psychotherapy for anxiety disorders: A meta-analytic review. Cognitive Behaviour Therapy. 2009;38:66-82. [pmid: 20183688].
Dallery J, Glenn IM, Raiff BR. An Internet-based abstinence reinforcement treatment for cigarette smoking. Drug and Alcohol Dependence. 2007;86:230-238. [pmid: 16930854].
Danaher BG, McKay HG, Seeley JR. The information architecture of behavior change Websites. Journal of Medical Internet Research. 2005;7:e12. [pmid: 15914459].
Danaher BG, Smolkowski K, Seeley JR, Severson HH. Mediators of a successful Web-based smokeless tobacco cessation program. Addiction. 2008;103:1706-1712. [pmid: 18715238].
de Graaf LE, Gerhards SAH, Arntz A, Riper H, Metsemakers JFM, Evers SM, Huibers MJ. One-year follow-up results of unsupported online computerized cognitive behavioural therapy for depression in primary care: A randomized trial. Journal of Behavior Therapy and Experimental Psychiatry. 2011;42:89-95. [pmid: 20723885].
Dorstyn DS, Mathias JL, Denson LA. Psychosocial outcomes of telephone-based counseling for adults with an acquired physical disability: A meta-analysis. Rehabilitation Psychology. 2011;56:1-14. [pmid: 21401281].
Eakin EG, Lawler SP, Vandelanotte C, Owen N. Telephone interventions for physical activity and dietary behavior change: A systematic review. American Journal of Preventive Medicine. 2007;32:419-434. [pmid: 17478269].
Ehrenreich B, Righter B, Rocke DA, Dixon L, Himelhoch S. Are mobile phones and handheld computers being used to enhance delivery of psychiatric treatment? A systematic review. Journal of Nervous and Mental Disease. 2011;199:886-891. [pmid: 22048142].
Eyrich-Garg KM. Mobile phone technology: A new paradigm for the prevention, treatment, and research of the non-sheltered “street” homeless?. Journal of Urban Health. 2010;87:365-380. [pmid: 20397058].
Farabee D, Cousins SJ, Brecht ML, Antonini VP, Lee AB, Brummer J, Rawson RA. A comparison of four telephone-based counseling styles for recovering stimulant users. Psychology of Addictive Behaviors. 2013;27(1):223-229. [pmid: 22867295].
Fjeldsoe BS, Marshall AL, Miller YD. Behavior change interventions delivered by mobile telephone short-message service. American Journal of Preventive Medicine. 2009;36:165-173. [pmid: 19135907].
Foley L, Maddison R. Use of active video games to increase physical activity in children: A (virtual) reality?. Pediatric Exercise Science. 2010;22:7-20. [pmid: 20332536].
Free C, Knight R, Robertson S, Whittaker R, Edwards P, Zhou W, Roberts I. Smoking cessation support delivered via mobile phone text messaging (txt2stop): A single-blind, randomised trial. The Lancet. 2011;378:49-55.
García-Lizana F, Muñoz-Mayorga I. Telemedicine for depression: A systematic review. Perspectives in Psychiatric Care. 2010;46:119-126. [pmid: 20377799].
García-Lizana F, Muñoz-Mayorga I. What about telepsychiatry? A systematic review. Primary Care Companion to the Journal of Clinical Psychiatry. 2010;12.
Gerardi M, Cukor J, Difede J, Rizzo A, Rothbaum BO. Virtual reality exposure therapy for post-traumatic stress disorder and other anxiety disorders. Current Psychiatry Reports. 2010;12:298-305. [pmid: 20535592].
Gibbons RD, Weiss DJ, Kupfer DJ, Frank E, Fagiolini A, Grochocinski VJ, Immekus JC. Using computerized adaptive testing to reduce the burden of mental health assessment. Psychiatric Services. 2008;59:361-368. [pmid: 18378832].
Griffiths MK, Calear LA, Banfield M. Systematic review on Internet support groups (ISGs) and depression (1): Do ISGs reduce depressive symptoms?. Journal of Medical Internet Research. 2009;11:e40. [pmid: 19793719].
Hedman E, Andersson E, Ljotsson B, Andersson G, Ruck C, Lindefors N. Cost-effectiveness of Internet-based cognitive behavior therapy vs. cognitive behavioral group therapy for social anxiety disorder: Results from a randomized controlled trial. Behaviour Research and Therapy. 2011;49:729-736. [pmid: 21851929].
Heron KE, Smyth JM. Ecological momentary interventions: Incorporating mobile technology into psychosocial and health behaviour treatments. British Journal of Health Psychology. 2010;15:1-39. [pmid: 19646331].
Hester RK, Squires DD, Delaney HD. The Drinker's Check-up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. Journal of Substance Abuse Treatment. 2005;28:159-169. [pmid: 15780546].
Hile MG, Adkins RE. Do substance abuse and mental health clients prefer automated assessments?. Behavior Research Methods, Instruments & Computers. 1997;29:146-150.
Hyler SE, Gangure DP, Batchelder ST. Can telepsychiatry replace in-person psychiatric assessments? A review and meta-analysis of comparison studies. CNS Spectrums. 2005;10:403-413. [pmid: 15858458].
Jones EG, Goldsmith M, Effken J, Button K, Crago M. Creating and testing a Deaf-friendly, stop-smoking web site intervention. American Annals of the Deaf. 2010;155:96-102. [pmid: 20503910].
Kaltenthaler E, Parry G, Beverley C, Ferriter M. Computerised cognitive–behavioural therapy for depression: Systematic review. British Journal of Psychiatry. 2008;193:181-184. [pmid: 18757972].
Kanani K, Regehr C. Clinical, ethical, and legal issues in e-therapy. Families in Society. 2003;84:155-162.
Kiluk BD, Sugarman DE, Nich C, Gibbons CJ, Martino S, Rounsaville BJ, Carroll KM. A methodological analysis of randomized clinical trials of computer-assisted therapies for psychiatric disorders: Toward improved standards for an emerging field. American Journal of Psychiatry. 2011;168:790-799. [pmid: 21536689].
Kim SI, Kim HS. Effectiveness of mobile and Internet intervention in patients with obese type 2 diabetes. International Journal of Medical Informatics. 2008;77:399-404. [pmid: 17881285].
Knealing TW, Wong CJ, Diemer KN, Hampton J, Silverman K. A randomized controlled trial of the therapeutic workplace for community methadone patients: A partial failure to engage. Experimental and Clinical Psychopharmacology. 2006;14:350-360. [pmid: 16893278].
Lin J-L, Vahabzadeh M, Mezghanni M, Epstein DH, Preston KL. A high-level specification for adaptive ecological momentary assessment: Real-time assessment of drug craving, use and abstinence. AMIA Annual Symposium Proceedings. 2005:455-459. [pmid: 16779081].
Lovejoy TI, Demireva PD, Grayson JL, McNamara JR. Advancing the practice of online psychotherapy: An application of Rogers' diffusion of innovations theory. Psychotherapy: Theory, Research, Practice, Training. 2009;46:112-124.
Lustria ML, Cortese J, Noar SM, Glueckauf RL. Computer-tailored health interventions delivered over the Web: Review and analysis of key components. Patient Education and Counseling. 2009;74:156-173. [pmid: 18947966].
Marsch LA. Technology-based interventions targeting substance use disorders and related issues: An editorial. Substance Use & Misuse. 2011;46:1-3. [pmid: 21190400].
McKay JR, Lynch KG, Shepard DS, Ratichek S, Morrison R, Koppenhaver J, Pettinati HM. The effectiveness of telephone-based continuing care in the clinical management of alcohol and cocaine use disorders: 12-month outcomes. Journal of Consulting and Clinical Psychology. 2004;72:967-979. [pmid: 15612844].
Mohr DC, Siddique J, Ho J, Duffecy J, Jin L, Fokuo JK. Interest in behavioral and psychological treatments delivered face-to-face, by telephone, and by Internet. Annals of Behavioral Medicine. 2010;40:89-98. [pmid: 20652466].
Mohr DC, Vella L, Hart S, Heckman T, Simon G. The effect of telephone-administered psychotherapy on symptoms of depression and attrition: A meta-analysis. Clinical Psychology (New York). 2008;15:243-253.
Moore BA, Fazzino T, Garnet B, Cutter CJ, Barry DT. Computer-based interventions for drug use disorders: A systematic review. Journal of Substance Abuse Treatment. 2011;40:215-223. [pmid: 21185683].
Muller I, Yardley L. Telephone-delivered cognitive behavioural therapy: A systematic review and meta-analysis. Journal of Telemedicine and Telecare. 2011;17:177-184. [pmid: 21357672].
Newman MG, Szkodny LE, Llera SJ, Przeworski A. A review of technology-assisted self-help and minimal contact therapies for anxiety and depression: Is human contact necessary for therapeutic efficacy?. Clinical Psychology Review. 2011;31:89-103. [pmid: 21130939].
Noar SM, Black HG, Pierce LB. Efficacy of computer technology-based HIV prevention interventions: A meta-analysis. AIDS. 2009;23:107-115. [pmid: 19050392].
Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention: A randomized trial with postpartum women. American Journal of Preventive Medicine. 2007;32:231-238. [pmid: 17236741].
Patten SB. Prevention of depressive symptoms through the use of distance technologies. Psychiatric Services. 2003;54:396-398. [pmid: 12610251].
Portnoy DB, Scott-Sheldon LAJ, Johnson BT, Carey MP. Computer-delivered interventions for health promotion and behavioral risk reduction: A meta-analysis of 75 randomized controlled trials, 1988–2007. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2008;47:3-16.
Postel MG, De Haan HA, De Jong CAJ. E-therapy for mental health problems: A systematic review. Telemedicine and e-Health. 2008;14:707-714. [pmid: 18817501].
Recupero PR. Legal concerns for psychiatrists who maintain Web sites. Psychiatric Services. 2006;57:450-452. [pmid: 16603737].
Revere D, Dunbar PJ. Review of computer-generated outpatient health behavior interventions: Clinical encounters “in absentia”. Journal of the American Medical Informatics Association. 2001;8:62-79. [pmid: 11141513].
Ritterband LM, Tate DF. The science of Internet interventions. Introduction. Annals of Behavioral Medicine. 2009;38:1-3. [pmid: 19816750].
Rotondi AJ, Anderson CM, Haas GL, Eack SM, Spring MB, Ganguli R, Rosenstock J. Web-based psychoeducational intervention for persons with schizophrenia and their supporters: One-year outcomes. Psychiatric Services. 2010;61:1099-1105. [pmid: 21041348].
Schinke S, Schwinn T, Cole K. Preventing alcohol abuse among early adolescents through family and computer-based interventions: Four-year outcomes and mediating variables. Journal of Developmental and Physical Disabilities. 2006;18:149-161. [pmid: 17215960].
Sholomskas DE, Syracuse-Siewert G, Rounsaville BJ, Ball SA, Nuro KF, Carroll KM. We don't train in vain: A dissemination trial of three strategies of training clinicians in cognitive-behavioral therapy. Journal of Consulting and Clinical Psychology. 2005;73:106-115. [pmid: 15709837].
Shore JH, Savin D, Novins D, Manson SM. Cultural aspects of telepsychiatry. Journal of Telemedicine and Telecare. 2006;12:116-121. [pmid: 16638232].
Smith B, Harms WD, Burres S, Korda H, Rosen H, Davis J. Enhancing behavioral health treatment and crisis management through mobile ecological momentary assessment and SMS messaging. Health Informatics Journal. 2012;18:294-308. [pmid: 23257059].
Stead LF, Perera R, Lancaster T. A systematic review of interventions for smokers who contact quitlines. Tobacco Control. 2007;16(Suppl 1):i3-i8. [pmid: 18048627].
Strecher V. Internet methods for delivering behavioral and health-related interventions (eHealth). Annual Review of Clinical Psychology. 2007;3:53-76.
Tate DF, Finkelstein EA, Khavjou O, Gustafson A. Cost-effectiveness of Internet interventions: Review and recommendations. Annals of Behavioral Medicine. 2009;38:40-45. [pmid: 19834778].
Tate DF, Zabinski MF. Computer and Internet applications for psychological treatment: Update for clinicians. Journal of Clinical Psychology. 2004;60:209-220. [pmid: 14724928].
Välimäki M, Hätönen H, Lahti M, Kuosmanen L, Adams CE. Information and communication technology in patient education and support for people with schizophrenia. Cochrane Database of Systematic Reviews. 2012;10. CD007198.
Waller R, Gilbody S. Barriers to the uptake of computerized cognitive behavioural therapy: A systematic review of the quantitative and qualitative evidence. Psychological Medicine. 2009;39:705-712. [pmid: 18812006].
Wantland DJ, Portillo CJ, Holzemer WL, Slaughter R, McGhee EM. The effectiveness of Web-based vs. non-Web-based interventions: A meta-analysis of behavioral change outcomes. Journal of Medical Internet Research. 2004;6:e40. [pmid: 15631964].
Webb TL, Joseph J, Yardley L, Michie S. Using the Internet to promote health behavior change: A systematic review and meta-analysis of the impact of theoretical basis, use of behavior change techniques, and mode of delivery on efficacy. Journal of Medical Internet Research. 2010;12:e4. [pmid: 20164043].
Weingardt KR, Cucciare MA, Bellotti C, Lai WP. A randomized trial comparing two models of Web-based training in cognitive behavioral therapy for substance abuse counselors. Journal of Substance Abuse Treatment. 2009;37:219-227. [pmid: 19339136].
Westphal A, Dingjan P, Attoe R. What can low and high technologies do for late-life mental disorders?. Current Opinion in Psychiatry. 2010;23:510-515. [pmid: 20717039].
White A, Kavanagh D, Stallman H, Klein B, Kay-Lambkin F, Proudfoot J, Young R. Online alcohol interventions: A systematic review. Journal of Medical Internet Research. 2010;12:e62. [pmid: 21169175].
Whittaker R, Borland R, Bullen C, Lin RB, McRobbie H, Rodgers A. 2009. Mobile phone-based interventions for smoking cessation. Cochrane Database of Systematic Reviews. CD006611.
Whittaker R, McRobbie H, Bullen C, Borland R, Rodgers A, Gu Y. Mobile phone-based interventions for smoking cessation. Cochrane Database of Systematic Reviews. 2012;11. CD006611.
Whitten P, Buis L. Private payer reimbursement for telemedicine services in the United States. Telemedicine Journal and e-Health. 2007;13:15-23. [pmid: 17309350].
Whitten P, Zaylor C, Kingsley C. An analysis of telepsychiatry programs from an organizational perspective. CyberPsychology and Behavior. 2000;3:911-916.
Yager Z, O'Dea JA. Prevention programs for body image and eating disorders on university campuses: A review of large, controlled interventions. Health Promotion International. 2008;23:173-189. [pmid: 18263883].