# A Practical Guide for the Provision of Behavioral Health Services

1 Part 1, Chapter 1

2 Part 1, Chapter 2