# Consensus Panel

Note: The information given indicates each participant's affiliation as of 2011, when the panel was convened, and may no longer reflect the individual's current affiliation.

Consensus Panels Chair
- Lisa A. Marsch, Ph.D.
  Director, Center for Technology and Behavioral Health
  Dartmouth Psychiatric Research Center
  Hanover, NH
  Former Director, Center for Technology and Health
  National Development and Research Institutes
  New York, NY

Part 1 Consensus Panelists
- Thomas J. Kim, M.D., M.P.H.
  Austin, TX
- Sarah Lord, Ph.D.
  Principal Investigator, Center for Technology and Health
  National Development and Research Institutes
  Cambridge, MA
- Richard N. Rosenthal, M.D.
  Chairman, Department of Psychiatry
  St. Luke's-Roosevelt Hospital Center
  New York, NY
- Cynthia B. Sternfeld, Ed.S.
  Lambertville, NJ
- Nancy R. VanDeMark, M.S.W., Ph.D.
  Wheat Ridge, CO

Part 2 Consensus Panelists
- Thelma McClosky Armstrong, M.A.
  Director
  Eastern Montana Telemedicine Network
  Billings, MT
- Nancy R. VanDeMark, M.S.W., Ph.D.
  Wheat Ridge, CO