# Acknowledgments

Numerous people contributed to the development of this Treatment Improvement Protocol (TIP), including the TIP Consensus Panel (p. v), the Stakeholders Meeting Participants (Appendix B), and the Field Reviewers (Appendix C).

This publication was produced under the Knowledge Application Program (KAP), a Joint Venture of The CDM Group, Inc. (CDM), and JBS International, Inc. (JBS), for the Substance Abuse and Mental Health Services Administration's Center for Substance Abuse Treatment.

CDM KAP personnel included Rose M. Urban, M.S.W., J.D., LCSW, LCAS, former Executive Project Co-Director; Jessica L. Culotta, M.A., Project Co-Director and former Managing Editor; Susan Kimner, former Managing Project Co-Director; Claudia Blackburn, Psy.D., Expert Content Director; Bruce Carruth, Ph.D., former Expert Content Director; Sheldon Weinberg, Ph.D., Senior Researcher/Applied Psychologist; Jonathan Max Gilbert, Ph.D., Editor/Writer; Angela Fiastro, Junior Editor; Virgie D. Paul, M.L.S., Librarian; and Maggie Nelson, former Project Coordinator.