# Field Reviewers

Note: The information given indicates each participant's affiliation as of 2012, when the review was conducted, and may no longer reflect the individual's current affiliation.

- John R. Bourdette, Ph.D.
  Professor
  Western New Mexico University
  Silver City, NM
- Ayanna V. Buckner, M.D., MPH, FACPM
  Associate Director, Public Health & General
  Preventive Medicine Residency Program
  Clinical Director, Department of Community Health & Preventive Medicine
  Morehouse School of Medicine
  Atlanta, GA
- Kenneth Drude, Ph.D.
  Board Member
  Ohio Board of Psychology
  Dayton, OH
- Bruce Goldman, LCSW, CASAC
  Director of Substance Abuse Services
  The Zucker Hillside Hospital
  Glen Oaks, NY
- Debra Guthmann, Ed.D., NIC
  Director of Pupil Personnel Services
  California School for the Deaf
  Fremont, CA
- Robert C. Freeman, Ph.D.
  Health Scientist Administrator
  National Institute on Alcohol Abuse and Alcoholism
  Bethesda, MD
- Dave Gustafson, Ph.D.
  Research Professor of Industrial and Systems Engineering
  University of Wisconsin-Madison
  Madison, WI
- Carmen Iacino, M.A., LAC
  Clinical Director
  West Slope Casa
  Glenwood Springs, CO
- Brian D. Kiluk, Ph.D.
  Assistant Professor
  Department of Psychiatry
  Yale School of Medicine
  Substance Abuse Treatment Unit (SATU)
  New Haven, CT
- Marlene M. Maheu, Ph.D.
  Executive Director
  TeleMental Health Institute, Inc.
  San Diego, CA
- Mary Ellen McAlevey, M.A., LPC, ACS, ATCS
  Licensed Professional Counselor
  Community Connection
  Long Branch, NJ
- Sandy McFall, M.A., LAC, NCACII
  Director
  Seven Cedars Education & Counseling Center LLC
  Clifton, CO
- Jay Ostrowski, M.A., LPC-S, NCC, DCC, ACS
  CEO
  Behavioral Health Innovation
  Ada, MI
- Howard Rosen, M.B.A.
  CEO
  LifeWIRE Corporation
  Toronto, Ontario
- Amy Smith
  Director
  Mindfreedom Colorado
  Denver, CO
- James A. Slade, Jr.
  Executive Board Member
  International Society for Mental Health Online
  Hyattsville, MD