# Stakeholders Meeting Participants

Note: The information given indicates each participant's affiliation as of 2011, when the panel was convened, and may no longer reflect the individual's current affiliation.

- Michael Ahmadi
  Public Health Analyst
  Office of Communications
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Girma Alemu
  Office of Health Information Technology and Quality
  Health Resources and Services Administration
  Rockville, MD
- Deepa Avula
  Acting Branch Chief
  Quality Improvement and Workforce Development Branch
  Division of Services Improvement
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Daniel Bailey
  Program Management Officer
  Division of Systems Development
  Center for Substance Abuse Prevention
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Jon Berg
  Public Health Advisor
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Christina Currier
  Government Project Officer
  Knowledge Application Program
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Donna Doolin, M.S.W., LCSW
  Public Health Advisor
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Suzanne L. Feldman, Ph.D.
  Public Health Advisor
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Reed Forman
  Lead Public Health Advisor
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Robert Freeman, Ph.D.
  Division of Epidemiology and Prevention Research
  National Institute on Alcohol Abuse and Alcoholism
  Bethesda, MD
- Linda Fulton
  Public Health Advisor
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Olinda Gonzalez
  Public Health Advisor
  Center for Mental Health Services
  Division of State and Community Systems Development
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Christopher Griffin
  1st Vice President
  National Alliance on Mental Illness of Maryland
  Columbia, MD
- Adam Haim, Ph.D.
  Chief
  Division of Services and Intervention Research
  Small Business Innovation Research/Small Business Technology Transfer Research Program
  Acting Chief
  Clinical Trials Operations and Biostatistics Unit
  Division of Services and Intervention
  National Institute on Mental Health
  National Institutes of Health
  Bethesda, MD
- Yael Harris, Ph.D.
  Director
  Office of Health Information Technology and Quality
  Health Resources and Services Administration
  Rockville, MD
- Rick Harwood
  Research and Program Applications Director
  National Association of State Alcohol and Drug Abuse Directors, Inc.
  Washington, DC
- Sharon Issurdatt, ACSW, DCSW, LCSW
  Senior Practice Associate
  National Association of Social Workers
  Washington, DC
- Ellen Jaffe
  American Psychiatric Association
  Arlington, VA
- Shoshana Kahana, Ph.D.
  National Institute on Drug Abuse
  Bethesda, MD
- Andrea Kopstein
  OPAC Division Supervisor
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- James Kretz, M.A.
  Survey Statistician
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Cherry Lowman, Ph.D.
  Extramural Scientist Administrator
  National Institutes of Health
  National Institute on Alcohol Abuse and Alcoholism
  Bethesda, MD
- Robert Lubran, M.P.H.
  Director
  Division of Pharmacologic Therapies
  Center for Substance Abuse Prevention
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Nancy Maher, Ph.D.
  Program Analyst
  Department of Veterans Affairs
  Office of Rural Health
  Washington, DC
- Lisa A. Marsch, Ph.D.
  Director, Center for Technology and Behavioral Health
  Dartmouth Psychiatric Research Center
  Hanover, NH
  Former Director, Center for Technology and Health
  National Development and Research Institutes
  New York, NY
- Karl Maxwell
  Public Health Advisor
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Cynthia Moreno Tuohy, NCAC II, CCDC III, SAP
  National Association of Alcoholism and Drug Abuse Counselors
  The Association for Addiction Professionals
  Alexandria, VA
- Charlotte A. Mullican, M.P.H.
  Senior Advisor for Mental Health Research
  Center for Primary Care, Prevention, and Clinical Partnership
  Agency for Healthcare Research and Quality
  Rockville, MD
- Catherine Njiru
  Lead Enterprise Architect
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Charlotte Olson
  Public Health Advisor
  Center for Substance Abuse Prevention
  Substance Abuse and Mental Health Services Administration
  Division of Community Programs
  Rockville, MD
- Dena S. Puskin, Sc.D.
  Senior Advisor
  Health Information Technology and Telehealth Policy
  Health Resources and Services Administration
  Rockville, MD
- Kenneth Robertson
  Team Leader Criminal Justice
  Center for Substance Abuse Treatment
  Division of Services Improvement
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Pat Shea, M.S.W., M.A.
  Deputy Director
  Office of Technical Assistance
  National Association of State Mental Health Program Directors
  Alexandria, VA
- James A. Slade
  Executive Board Member
  International Society for Mental Health Online
  Hyattsville, MD
- Carlton Speight
  Substance Abuse and Mental Health Services Administration
- Arlene Stanton, Ph.D.
  Social Science Analyst
  Division of Pharmacologic Therapies
  Substance Abuse and Mental Health Services Administration
  Rockville, MD