# Bibliography

Abbass A, Arthey S, Elliott J, Fedak T, Nowoweiski D, Markovski J, Nowoweiski S. Web-conference supervision for advanced psychotherapy training: A practical guide. Psychotherapy. 2011;48:109-118. [pmid: 21639654].
Abbott JA, Klein B, Ciechomski L. Best practices in online therapy. Journal of Technology in Human Services. 2008;26:360-375.
Alemi F, Haack MR, Nemes S, Aughburns R, Sinkule J, Neuhauser D. Therapeutic emails. Substance Abuse Treatment, Prevention, and Policy. 2007;2.
American Counseling Association. 2005. ACA code of ethics. Alexandria, VA. American Counseling Association.
American Medical Association. 2000. Guidelines for patient–physician electronic mail. Chicago. American Medical Association.
American Mental Health Counselors Association. 2000. Code of ethics of the American Mental Health Counselors Association. Alexandria, VA. American Mental Health Counselors Association.
American Psychiatric Association. 2013. Diagnostic and statistical manual of mental disorders. 5th ed. Arlington, VA. American Psychiatric Association.
American Psychological Association. 1997. APA statement on services by telephone, teleconferencing, and internet: A statement by the Ethics Committee of the American Psychological Association. Washington, DC. American Psychological Association.
American Psychological Association. 2010. Ethical principles of psychologists and code of conduct. Washington, DC. American Psychological Association.
American Psychological Association. 2012. New generation of virtual humans helping to train psychologists. Washington, DC. American Psychological Association.
American Telemedicine Association. 2009. Evidence-based practice for telemental health. Washington, DC. American Psychological Association.
American Telemedicine Association. 2009. Practice guidelines for videoconferencing-based telemental health. Washington, DC. American Psychological Association.
American Telemedicine Association. 2010. US states. Washington, DC. American Psychological Association.
Andersson G, Carlbring P, Berger T, Almlöv J, Cuijpers P. What makes internet therapy work?. Cognitive Behaviour Therapy. 2009;1.
Andersson G, Carlbring P, Grimlund A. Predicting treatment outcome in internet versus face to face treatment of panic disorder. Computers in Human Behavior. 2008;24:1790-1801.
Andersson G, Cuijpers P. Internet-based and other computerized psychological treatments for adult depression: A meta-analysis. Cognitive Behaviour Therapy. 2009;38:196-205. [pmid: 20183695].
Andre B, Ringdal GI, Loge JH, Rannestad T, Kaasa S. The importance of key personnel and active management for successful implementation of computer-based technology in palliative care: Results from a qualitative study. CIN - Computers Informatics Nursing. 2008;26:183-189.
Anthony K, Jamison A. 2005. Guidelines for online counselling & psychotherapy, including guidelines for online supervision. 2nd edition. Lutterworth, England. British Association for Counselling and Psychotherapy.
Anthony K, Nagel DM, Goss S. 2010. The use of technology in mental health: Applications, ethics and practice. Springfield, IL. Charles C. Thomas Publishers.
APA Practice Organization. 2011. Reimbursement for telehealth services. Washington DC. APA Practice Central.
Aronson ID, Plass JL, Bania TC. Optimizing educational video through comparative trials in clinical environments. Educational Technology Research and Development. 2012;60:469-482. [pmid: 22904607].
Association of Canadian Psychology Regulatory Organizations. 2011. Model standards for telepsychology service delivery. Toronto, Canada. Association of Canadian Psychology Regulatory Organizations.
Aukstakalnis S, Blattner D. 1992. Silicon mirage: The art and science of virtual reality. Berkeley, CA. Peachpit Press.
Australian Psychological Society. 2004. Guidelines for providing psychological services and products on the internet. Melbourne, Australia. Australian Psychological Society.
Backhaus A, Agha Z, Maglione ML, Repp A, Ross B, Zuest D, Thorp SR. Videoconferencing psychotherapy: A systematic review. Psychological Services. 2012;9:111-131. [pmid: 22662727].
Barak A, Boneh O, Dolev-Cohen M. Factors underlying participants' gains in online support groups. Blachnio A, Przepiorka A, Rowiński T, editors. Internet in psychological research. 2010:17-38. Warsaw, Poland. Cardinal Stefan Wyszyński University Press.
Barak A, Boniel-Nissim M, Suler J. Fostering empowerment in online support groups. Computers in Human Behavior. 2008;24:1867-1883.
Barak A, Hen L, Boniel-Nissim M, Shapira N. A comprehensive review and a meta-analysis of the effectiveness of internet-based psychotherapeutic interventions. Journal of Technology in Human Services. 2008;26:109-160.
Barak A, Klein B, Proudfoot JG. Defining internet-supported therapeutic interventions. Annals of Behavioral Medicine. 2009;38:4-17. [pmid: 19787305].
Barak A, Meyran B, John S. Fostering empowerment in online support groups. Computers in Human Behavior. 2008;24:1867-1883.
Barak A, Wander-Schwartz M. Empirical evaluation of brief group therapy conducted in an internet chat room. Journal of Virtual Environments. 2000;5(1).
Barlow JH, Ellard DR, Hainsworth JM, Jones FR, Fisher A. A review of self-management interventions for panic disorders, phobias and obsessive–compulsive disorders. Acta Psychiatrica Scandinavica. 2005;111:272-285. [pmid: 15740463].
Barnett JE. Utilizing technological innovations to enhance psychotherapy supervision, training, and outcomes. Psychotherapy. 2011;48:103-108. [pmid: 21639653].
Barnett NP, Tidey J, Murphy JG, Swift R, Colby SM. Contingency management for alcohol use reduction: A pilot study using a transdermal alcohol sensor. Drug and Alcohol Dependence. 2011;118:391-399. [pmid: 21665385].
Barnwell SV, Juretic MA, Hoerster KD, Van de Plasch R, Felker BL. VA Puget Sound Telemental Health Service to rural veterans: A growing program. Psychological Services. 2012;9:209-211. [pmid: 22662737].
Beck AT, Rush AJ, Shaw BF, Emery G. 1979. Cognitive therapy of depression. New York. Guilford Press.
Ben-Zeev D, Brenner CJ, Begale M, Duffecy J, Mohr DC, Mueser KT. 2014. Feasibility, acceptability, and preliminary efficacy of a smartphone intervention for schizophrenia. Schizophrenia Bulletin. Lebanon, NH. Dartmouth Psychiatric Research Center.
Ben-Zeev D, McHugo GJ, Xie H, Dobbins K, Young MA. Comparing retrospective reports to real-time/real-place mobile assessment in individuals with schizophrenia and a nonclinical comparison group. Schizophrenia Bulletin. 2012;38:396-404. [pmid: 22302902].
Bickel WK, Marsch LA, Buchhalter AR, Badger GJ. Computerized behavior therapy for opioid-dependent outpatients: A randomized controlled trial. Experimental and Clinical Psychopharmacology. 2008;16:132-143. [pmid: 18489017].
Bickel WK, Marsch LA, Budney AJ. Technology-delivered treatments for substance use disorders: Current status and future directions. Miller PM, editor. Interventions for Addiction: Comprehensive Addictive Behaviors and Disorders. 2013;3:275-285. Oxford, England. Elsevier Limited.
Billings G. 2012. Michigan becomes 15th state to pass private payer telehealth reimbursement. Washington DC. Center for Telehealth and e-Health Law.
Blankers M, Koeter MWJ, Schippers GM. Internet therapy versus internet self-help versus no treatment for problematic alcohol use: A randomized controlled trial. Journal of Consulting and Clinical Psychology. 2011;79:330-341. [pmid: 21534652].
Bopp JM, Miklowitz DJ, Goodwin GM, Stevens W, Rendell JM, Geddes JR. The longitudinal course of bipolar disorder as revealed through weekly text messaging: a feasibility study. Bipolar Disorders. 2010;12:327-334. [pmid: 20565440].
Bowman D. 2012. Telemedicine bill enables VA providers to practice across state lines. Washington DC. Fierce Markets.
Boyer EW, Smelson D, Fletcher R, Ziedonis D, Picard RW. Wireless technologies, ubiquitous computing and mobile health: Application to drug abuse treatment and compliance with HIV therapies. Journal of Medical Toxicology. 2010;6:212-216. [pmid: 20623215].
Brendryen H, Drozd F, Kraft P. A digital smoking cessation program delivered through internet and cell phone without nicotine replacement (happy ending): Randomized controlled trial. Journal of Medical Internet Research. 2008;10:e51. [pmid: 19087949].
Brendryen H, Kraft P. Happy ending: A randomized controlled trial of a digital multi-media smoking cessation intervention. Addiction. 2008;103:478-484. [pmid: 18269367].
Brenes GA, Ingram CW, Danhauer SC. Telephone-delivered psychotherapy for late-life anxiety. Psychological Services. 2012;9:219-220. [pmid: 22662740].
Brennan JM Jr. 2013. Using virtual reality to improve resilience. Gahanna, OH. The National Psychologist.
British Psychological Society. 2009. The provision of psychological services via the internet and other non-direct means. Leicester, England. British Psychological Society.
Broadband Adoption Act of 2015, S.1472. 114th Cong. 2015.
Brunette MF, Ferron JC, McHugo GJ, Davis KE, Devitt TS, Drake RE. An electronic decision support system to motivate people with severe mental illnesses to quit smoking. Psychiatric Services. 2011;62:360-366. [pmid: 21459986].
Buglione SA, DeVito AJ, Mulloy JM. Traditional group therapy and computer-administered treatment for test anxiety. Anxiety Research. 1990;3:33-39.
Bunz U. The computer-email-web (CEW) fluency scale - Development and validation. International Journal of Human-Computer Interaction. 2004;17:479-506.
Burleson JA, Kaminer Y. Aftercare for adolescent alcohol use disorder: Feasibility and acceptability of a phone intervention. The American Journal on Addictions. 2007;16:202-205. [pmid: 17612824].
Byrne AM, Hartley MT. Digital technology in the 21st century: Considerations for clinical supervision in rehabilitation education. Rehabilitation Education. 2010;24:57-68.
California Telemedicine & eHealth Center. 2006. Telemedicine reimbursement handbook. Sacramento, CA. California Telemedicine & eHealth Center.
Campbell ANC, Nunes EV, Mathews AG, Stitzer M, Miele GM, Polsky D, Goldman B. Internet-delivered treatment for substance abuse: A multisite randomized controlled trial. American Journal of Psychiatry. 2014;171(6):683-690. [pmid: 24700332].
Canadian Psychological Association. 2006. Ethical guidelines for psychologists providing psychological services via electronic media. Ottawa, Canada. Canadian Psychological Society.
Capezza NM, Najavits LM. Rates of trauma-informed counseling at substance abuse treatment facilities: Reports from over 10,000 programs. Psychiatric Services. 2012;63:390-394. [pmid: 22476307].
Carise D, Gurel O, McLellan AT, Dugosh K, Kendig C. Getting patients the services they need using a computer-assisted system for patient assessment and referral—CASPAR. Drug and Alcohol Dependence. 2005;80:177-189. [pmid: 15913922].
Carr AC, Ghosh A, Marks IM. Computer-supervised exposure treatment for phobias. Canadian Journal of Psychiatry. 1988;33:112-117. [pmid: 3365636].
Carroll KM, Ball SA, Martino S, Nich C, Babuscio TA, Nuro KF, Rounsaville BJ. Computer-assisted delivery of cognitive–behavioral therapy for addiction: A randomized trial of CBT4CBT. The American Journal of Psychiatry. 2008;165:881-888. [pmid: 18450927].
Carroll KM, Kiluk BD, Nich C, Gordon MA, Portnoy GA, Marino DR, Ball SA. Computer-assisted delivery of cognitive-behavioral therapy: Efficacy and durability of CBT4CBT among cocaine-dependent individuals maintained on methadone. American Journal of Psychiatry. 2014;171(4):436-444. [pmid: 24577287].
Carroll KM, Nich C, Ball SA. Practice makes progress? Homework assignments and outcome in treatment of cocaine dependence. Journal of Consulting and Clinical Psychology. 2005;73:749-755. [pmid: 16173864].
Carroll KM, Rounsaville BJ. Computer-assisted therapy in psychiatry: Be brave—it's a new world. Current Psychiatry Reports. 2010;12:426-432. [pmid: 20683681].
Center for Substance Abuse Treatment. 1993. Improving treatment for drug-exposed infants. Treatment Improvement Protocol (TIP) Series 5. HHS Publication No. SMA) 95-3057. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Pregnant, substance-using women. Treatment Improvement Protocol (TIP) Series 2. HHS Publication No. (SMA) 93-1998. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Screening for infectious diseases among substance abusers. Treatment Improvement Protocol (TIP) Series 6. HHS Publication No. (SMA) 95-3060. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1994. Simple screening instruments for outreach for alcohol and other drug abuse and infectious diseases. Treatment Improvement Protocol (TIP) Series 11. HHS Publication No (SMA) 94-2094). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Alcohol and other drug screening of hospitalized trauma patients. Treatment Improvement Protocol (TIP) Series 16. HHS Publication No. (SMA) 95-3041. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Combining alcohol and other drug treatment with diversion for juveniles in the justice system. Treatment Improvement Protocol (TIP) Series 21. (HHS Publication No (SMA) 95-3051). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Developing state outcomes monitoring systems for alcohol and other drug abuse treatment. Treatment Improvement Protocol (TIP) Series 14. HHS Publication No. (SMA) 95-3031. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The role and current status of patient placement criteria in the treatment of substance use disorders. Treatment Improvement Protocol (TIP) Series 13. HHS Publication No. (SMA) 95-3021. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The tuberculosis epidemic: Legal and ethical issues for alcohol and other drug abuse treatment providers. Treatment Improvement Protocol (TIP) Series 18. HHS Publication No. (SMA) 95-3047. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1996. Treatment drug courts: Integrating substance abuse treatment with legal case processing. Treatment Improvement Protocol (TIP) Series 23. HHS Publication No. (SMA) 96-3113. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. A guide to substance abuse services for primary care clinicians. Treatment Improvement Protocol (TIP) Series 24. HHS Publication No. (SMA) 97-3139. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. Substance abuse treatment and domestic violence. Treatment Improvement Protocol (TIP) Series 25. HHS Publication No. (SMA) 97-3163. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Comprehensive case management for substance abuse treatment. Treatment Improvement Protocol (TIP) Series 27. HHS Publication No. (SMA) 98-3222. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Continuity of offender treatment for substance use disorders from institution to community. Treatment Improvement Protocol (TIP) Series 30. HHS Publication No. (SMA) 98-3245. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Naltrexone and alcoholism treatment. Treatment Improvement Protocol (TIP) Series 28. HHS Publication No. (SMA) 98-3206. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance abuse among older adults. Treatment Improvement Protocol (TIP) Series 26. HHS Publication No. (SMA) 98-3179. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance use disorder treatment for people with physical and cognitive disabilities. Treatment Improvement Protocol (TIP) Series 29. HHS Publication No. (SMA) 98-3249. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Brief interventions and brief therapies for substance abuse. Treatment Improvement Protocol (TIP) Series 34. HHS Publication No. (SMA) 99-3353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Enhancing motivation for change in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 35. HHS Publication No. (SMA) 99-3354. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Screening and assessing adolescents for substance use disorders. Treatment Improvement Protocol (TIP) Series 31. HHS Publication No. (SMA) 99-3282. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment for stimulant use disorders. Treatment Improvement Protocol (TIP) Series 33. HHS Publication No. (SMA) 99-3296. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment of adolescents with substance use disorders. Treatment Improvement Protocol (TIP) Series 32. HHS Publication No. (SMA) 99-3283. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Integrating substance abuse treatment and vocational services. Treatment Improvement Protocol (TIP) Series 38. HHS Publication No. (SMA) 00-3470. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with child abuse and neglect issues. Treatment Improvement Protocol (TIP) Series 36. HHS Publication No. (SMA) 00-3357. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37. HHS Publication No. (SMA) 00-3459. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Clinical guidelines for the use of buprenorphine in the treatment of opioid addiction. Treatment Improvement Protocol (TIP) Series 40. HHS Publication No. (SMA) 04-3939. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Substance abuse treatment and family therapy. Treatment Improvement Protocol (TIP) Series 39. HHS Publication No. (SMA) 04-3957. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. The confidentiality of alcohol and drug abuse patient records regulation and the HIPAA Privacy Rule: Implications for alcohol and substance abuse programs. HHS Publication No. (SMA) 04-3947. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Medication-assisted treatment for opioid addiction. Treatment Improvement Protocol (TIP) Series 43. HHS Publication No. (SMA) 05-4048. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for adults in the criminal justice system. Treatment Improvement Protocol (TIP) Series 44. HHS Publication No. (SMA) 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for persons with co-occurring disorders. Treatment Improvement Protocol (TIP) Series 42. HHS Publication No. (SMA) 05-3992. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment: Group therapy. Treatment Improvement Protocol (TIP) Series 41. HHS Publication No. (SMA) 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Detoxification and substance abuse treatment. Treatment Improvement Protocol (TIP) Series 45. HHS Publication No. (SMA) 06-4131. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Administrative issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 46. HHS Publication No. (SMA) 06-4151. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Clinical issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 47. HHS Publication No. (SMA) 06-4182. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2008. Managing depressive symptoms in substance abuse clients during early recovery. Treatment Improvement Protocol (TIP) Series 48. HHS Publication No. (SMA) 08-4353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Addressing suicidal thoughts and behaviors in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 50. HHS Publication No. (SMA) 09-4381. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Clinical supervision and the professional development of the substance abuse counselor. Treatment Improvement Protocol (TIP) Series 52. HHS Publication No. (SMA) 09-4435. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Considerations for the provision of e-therapy. HHS Publication No. (SMA) 09-4450. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Incorporating alcohol pharmacotherapies into medical practice. Treatment Improvement Protocol (TIP) Series 49. HHS Publication No. (SMA) 09-4380. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Substance abuse treatment: Addressing the specific needs of women. Treatment Improvement Protocol (TIP) Series 51. HHS Publication No. (SMA) 09-4426. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Technology and Aging. 2010. Medication optimization. Oakland, CA. Center for Technology and Aging.
Chambers M, Connors SL, McElhinney S. Substance use and young people: The potential of technology. Journal of Psychiatric and Mental Health Nursing. 2005;12:179-186. [pmid: 15788035].
Chambless DL, Hollon SD. Defining empirically supported therapies. Journal of Consulting and Clinical Psychology. 1998;66:7-18. [pmid: 9489259].
Chandler GM, Burck H, Sampson JP, Wray R. The effectiveness of a generic computer program for systematic desensitization. Computers in Human Behavior. 1988;4:339-346.
Chen ZW, Fang LZ, Chen LY, Dai HL. Comparison of an SMS text messaging and phone reminder to improve attendance at a health promotion center: A randomized controlled trial. Journal of Zhejiang University Science B. 2008;9:34-38. [pmid: 18196610].
Chiauzzi E, Brevard J, Thurn C, Decembrele S, Lord S. MyStudentBody-stress: An online stress management intervention for college students. Journal of Health Communication. 2008;13:555-572. [pmid: 18726812].
Chiauzzi E, Green TC, Lord S, Thum C, Goldstein M. My student body: A high-risk drinking prevention web site for college students. Journal of American College Health. 2005;53:263-274. [pmid: 15900990].
Cho JH, Lee HC, Lim DJ, Kwon HS, Yoon KH. Mobile communication using a mobile phone with a glucometer for glucose control in Type 2 patients with diabetes: as effective as an internet-based glucose monitoring system. Journal of Telemedicine and Telecare. 2009;15:77-82. [pmid: 19246607].
Choudhury T, Consolvo S, Harrison B, LaMarca A, LeGrand L, Rahimi A, Haehnel D. The mobile sensing platform: An embedded activity recognition system. IEEE Pervasive Computing. 2008;7:32-41.
Chung-Do J, Helm S, Fukuda M, Alicata D, Nishimura S, Else I. Rural mental health: Implications for telepsychiatry in clinical service, workforce development, and organizational capacity. Journal of Telemedicine and eHealth. 2012;18(3):244-246.
Cole-Lewis H, Kershaw T. Text messaging as a tool for behavior change in disease prevention management. Epidemiology Review. 2010;32:56-69.
Collins F. How to fulfill the true promise of “mHealth”. Scientific American. 2012;307:16. [pmid: 22779258].
Consolvo S, Landay JA, McDonald DW. Designing for behavior change in everyday life. Computer. 2009;42:86-89.
Cuijpers P, Marks IM, van Straten A, Cavanagh K, Gega L, Andersson G. Computer-aided psychotherapy for anxiety disorders: A meta-analytic review. Cognitive Behaviour Therapy. 2009;38:66-82. [pmid: 20183688].
Dallery J, Glenn IM. Effects of an Internet-based voucher reinforcement program for smoking abstinence: A feasibility study. Journal of Applied Behavior Analysis. 2005;38:349-357. [pmid: 16270844].
Dallery J, Glenn IM, Raiff BR. An internet-based abstinence reinforcement treatment for cigarette smoking. Drug and Alcohol Dependence. 2007;86:230-238. [pmid: 16930854].
Danaher BG, McKay HG, Seeley JR. The information architecture of behavior change websites. Journal of Medical Internet Research. 2005;7:e12. [pmid: 15914459].
Daoust J-P, Renaud M, Bruyère B, Lemieux V, Fleury G, Najavits LM. 2012. Posttraumatic stress disorder and substance use disorder: Evaluation of the effectiveness of a specialized clinic for French-Canadians based in a teaching hospital. Retrieved October 7, 2013 from: http://www.seekingsafety.org/3-03-06/studies.html#Men_and_women.
Day X, Schneider PL. Psychotherapy using distance technology: A comparison of face-to-face, video, and audio treatment. Journal of Counseling Psychology. 2002;49:499-503.
Derrig-Palumbo K. Using chat and instant messaging (IM) to conduct a therapeutic relationship. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:15-28. Springfield, IL. Charles C. Thomas Publishers.
Des Jarlais DC, Paone D, Milliken J, Turner CF, Miller H, Gribble J, Friedman SR. Audio-computer interviewing to measure risk behaviour for HIV among injecting drug users: A quasi-randomised trial. The Lancet. 1999;353:1657-1661.
Detweiler MB, Arif S, Candelario J, Altman J, Murphy PF, Halling MH, Detweiler JG. Salem VA MC-US Army Fort Bragg Warrior Transition Clinic telepsychiatry collaboration: 12-month operation clinical perspective. Journal of Telemedicine and eHealth. 2012;18(2):81-86.
Digital Learning Equity Act of 2015 S.1606. 114th Cong. 2015.
Downer SR, Meara JG, Da Costa AC, Sethuraman K. SMS text messaging improves outpatient attendance. Australian Health Review. 2006;30:389-396. [pmid: 16879098].
Drake RE, Bond GR. Implementing integrated mental health and substance abuse services. Journal of Dual Diagnosis. 2010;6:251-262.
Duggan M, Ellison NB, Lampe C, Lenhart A, Madden M. 2015. Social media update 2014. Washington, DC. Pew Research Center.
Eakin EG, Lawler SP, Vandelanotte C, Owen N. Telephone interventions for physical activity and dietary behavior change: A systematic review. American Journal of Preventive Medicine. 2007;32:419-434. [pmid: 17478269].
Egede LE, Frueh CB, Richardson LK, Acierno R, Mauldin PD, Knapp RG, Lejuez C. Rationale and design: Telepsychology service delivery for depressed elderly veterans. Trials. 2009;10:22. [pmid: 19379517].
Elenko E, Speier A, Zohar D. A regulatory framework emerges for digital medicine. Nature Biotechnology. 2015;33:697-702.
Ellis A, Harper RA. 1975. A new guide to rational living. Oxford, England. Prentice-Hall.
Emmelkamp PM. Attention bias modification: The emperor's new suit?. BMC Medicine. 2012;10:63. [pmid: 22731990].
Ertin E, Stohs N, Kumar S, Raijt A, al Absi M, Shah S. 2011. Autosense: Unobtrusively wearable sensor suite for inferring the onset, causality, and consequences of stress in the field. New York. Association for Computing Machinery.
Facebook. 2015. Stats—Facebook newsroom. Retrieved June 24, 2015 from: http://newsroom.fb.com/company-info.
Farvolden P, Cunningham J, Selby P. Using e-health programs to overcome barriers to the effective treatment of mental health and addiction problems. Journal of Technology in Human Services. 2009;27:5-22.
Favela J, Tentori M, Gonzalez VM. Ecological validity and pervasiveness in the evaluation of ubiquitous computing technologies for health care. International Journal of Human-Computer Interaction. 2010;26:414-444.
Federal Communications Commission. 2015. FCC Chairman Wheeler seeks comment on modernizing lifeline to make 21st century broadband affordable for low-income households. Washington DC. Federal Communications Commission.
Federation of State Medical Boards of the United States. 2002. Model guidelines for the appropriate use of the internet in medical practice. Euless, TX. Federation of State Medical Boards of the United States, Special Committee on Professional Conduct and Ethics.
Finfgeld-Connett D, Madsen R. Web-based treatment of alcohol problems among rural women: Results of a randomized pilot investigation. Journal of Psychosocial Nursing and Mental Health Services. 2008;46:46-53. [pmid: 18823000].
Foley L, Maddison R. Use of active video games to increase physical activity in children: A (virtual) reality?. Pediatric Exercise Science. 2010;22:7-20. [pmid: 20332536].
Forducey PG, Glueckauf RL, Bergquist TF, Maheu MM, Yutsis M. Telehealth for persons with severe functional disabilities and their caregivers: Facilitating self-care management in the home setting. Psychological Services. 2012;9:144-162. [pmid: 22662729].
Forman R, Crits-Christoph P, Kaynak O, Worley M, Hantula DA, Kulaga A, Cawley M. A feasibility study of a web-based performance improvement system for substance abuse treatment providers. Journal of Substance Abuse Treatment. 2007;33:363-371. [pmid: 17499954].
Franklin V, Waller A, Pagliari C, Greene S. “Sweet talk”: Text messaging support for intensive insulin therapy for young people with diabetes. Diabetes Technology and Therapeutics. 2003;5:991-996. [pmid: 14709202].
Franklin VL, Waller A, Pagliari C, Greene SA. A randomized controlled trial of Sweet Talk, a text-messaging system to support young people with diabetes. Diabetic Medicine. 2006;23:1332-1338. [pmid: 17116184].
Free C, Knight R, Robertson S, Whittaker R, Edwards P, Zhou W, Roberts I. Smoking cessation support delivered via mobile phone text messaging (txt2stop): A single-blind, randomised trial. The Lancet. 2011;378:49-55.
Free C, Phillips G, Galli L, Watson L, Felix L, Edwards P, Haines A. The effectiveness of mobile-health technology-based health behavior change or disease management interventions for health care consumers: A systematic review. PLoS Medicine. 2013;10:e1001362. [pmid: 23349621].
Free C, Whittaker R, Knight R, Abramsky T, Rodgers A, Roberts IG. Txt2stop: A pilot randomised controlled trial of mobile phone-based smoking cessation support. Tobacco Control. 2009;18:88-91. [pmid: 19318534].
García-Lizana F, Muñoz-Mayorga I. Telemedicine for depression: A systematic review. Perspectives in Psychiatric Care. 2010;46(2):119-126. [pmid: 20377799].
García-Lizana F, Muñoz-Mayorga I. What about telepsychiatry? A systematic review. Primary Care Companion to the Journal of Clinical Psychiatry. 2010;12.
Gerber BS, Stolley MR, Thompson AL, Sharp LK, Fitzgibbon ML. Mobile phone text messaging to promote healthy behaviors and weight loss maintenance: A feasibility study. Health Informatics Journal. 2009;15:17-25. [pmid: 19218309].
Gibbons MC. 2007. eHealth solutions for healthcare disparities. New York. Springer Publications.
Gibbons MC, Fleisher L, Slamon RE, Bass S, Kandadai V, Beck JR. Exploring the potential of Web 2.0 to address health disparities. Journal of Health Communication. Supplement 1. 2011;16:77-89. [pmid: 21843097].
Gilman M, Stensland J. Telehealth and Medicare: Payment policy, current use, and prospects for growth. Medicare & Medicaid Research. 2013;3(4):E1-E13.
Glasgow RE, Bull SS, Piette JD, Steiner JF. Interactive behavior change technology: A partial solution to the competing demands of primary care. American Journal of Preventive Medicine. 2004;27:80-87. [pmid: 15275676].
Godleski L, Darkins A, Peters J. Outcomes of 98,609 U. S. Department of Veterans Affairs patients enrolled in telemental health services, 2006–2010. Psychiatric Services. 2012;63:383-385. [pmid: 22476305].
Golkaramnay V, Bauer S, Haug S, Wolf M, Kordy H. The exploration of the effectiveness of group therapy through an internet chat as aftercare: A controlled naturalistic study. Psychotherapy and Psychosomatics. 2007;76:219-225. [pmid: 17570960].
Graf NM, Stebnicki MA. Using e-mail for clinical supervision in practicum: A qualitative analysis. Journal of Rehabilitation. 2002;68:41-49.
Granholm E, Ben-Zeev D, Link PC, Bradshaw KR, Holden JL. Mobile assessment and treatment for schizophrenia (MATS): A pilot trial of an interactive text-messaging intervention for medication adherence, socialization, and auditory hallucinations. Schizophrenia Bulletin. 2012;38:414-425. [pmid: 22080492].
Green BL. Trauma history questionnaire. Stamm BH, editor. Measurement of stress, trauma, and adaptation. 1996:366-369. Lutherville, MD. Sidran Press.
Griffiths KM, Calear LA, Banfield M. Systematic review on internet support groups (ISGs) and depression (1): Do ISGs reduce depressive symptoms?. Journal of Medical Internet Research. 2009;11:e40. [pmid: 19793719].
Griffiths KM, Christensen H. Internet-based mental health programs: A powerful tool in the rural medical kit. The Australian Journal of Rural Health. 2007;15:81-87. [pmid: 17441815].
Gustafson DH, McTavish FM, Ming-Yuan C, Atwood AK, Johnson RA, Boyle MG, Shah D. A smartphone application to support recovery from alcoholism: A randomized clinical trial. JAMA. 2014;71(5):566-572.
Gustafson DH, Shaw BR, Isham A, Baker T, Boyle MG, Levy M. Explicating an evidence-based, theoretically informed, mobile technology-based system to improve outcomes for people in recovery for alcohol dependence. Substance Use & Misuse. 2011;46:96-111. [pmid: 21190410].
Guthmann D, Graham V. Substance abuse: A hidden problem within the D/deaf and hard of hearing communities. Journal of Teaching in the Addictions. 2005;3:49-64.
Hanley T, Reynolds DJ Jr. Counselling psychology and the internet: A review of the quantitative research into online outcomes and alliances within text-based therapy. Counselling Psychology Review. 2009;24:4-13.
Hasin DS, Aharonovich E, Greenstein E. HealthCall for the smartphone: Technology enhancement of brief intervention in HIV alcohol dependent patients. Addiction Science & Clinical Practice. 2014;9:5. [pmid: 24533631].
Hasson H, Brown C, Hasson D. Factors associated with high use of a workplace web-based stress management program in a randomized controlled intervention study. Health Education Research. 2010;25:596-607. [pmid: 20150531].
Haug S, Meyer C, Gross B, Schorr G, Thyrian JR, Kordy H, John U. Continuous individual support of smoking cessation in socially deprived young adults via mobile phones—Results of a pilot study. Gesundheitswesen. 2008;70:364-371. [pmid: 18661460].
Healthcare Information and Management Systems Society. 2011. Security of mobile computing devices in the healthcare environment. Chicago. Healthcare Information and Management Systems Society.
Hester RK, Delaney HD. Behavioral self-control program for Windows: Results of a controlled clinical trial. Journal of Consulting and Clinical Psychology. 1997;65:686-693. [pmid: 9256570].
Hester RK, Squires DD, Delaney HD. The drinker's check-up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. Journal of Substance Abuse Treatment. 2005;28:159-169. [pmid: 15780546].
Hoge MA, Morris JA, Daniels AS, Stuart GW, Huey LY, Adams N. 2007. An action plan for behavioral health workforce development: A framework for discussion. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Holtyn AF, Koffamus MN, DeFulio A, Sigurdsson SO, Strain EC, Schwartz RP, Silverman K. 2014. The therapeutic workplace to promote treatment engagement and drug abstinence in out-of-treatment injection drug users: A randomized controlled trial. Preventive Medicine.
Hooper LM, Stockton P, Krupnick JL, Green BL. Development, use, and psychometric properties of the trauma history questionnaire. Journal of Loss and Trauma. 2011;16:258-283.
Horrigan J. 2009. Wireless internet use. Washington, DC. Pew Research Center.
Hunkeler EM, Hargreaves WA, Fireman B, Terdiman J, Meresman JF, Porterfield Y, Taylor CB. A web-delivered care management and patient self-management program for recurrent depression: A randomized trial. Psychiatric Services. 2012;63(11):1063-1071. [pmid: 22983558].
Hustad JTP, Barnett NP, Borsari B, Jackson KM. Web-based alcohol prevention for incoming college students: A randomized controlled trial. Addictive Behaviors. 2010;35(3):183-189. [pmid: 19900763].
Institute of Medicine. 2006. Improving the quality of health care for mental and substance-use conditions: Quality chasm series. Washington, DC. Institute of Medicine.
Institute of Medicine. 2008. Treatment of posttraumatic stress disorder: An assessment of the evidence. Washington, DC. The National Academies Press.
Institute of Medicine. 2009. Preventing mental, emotional, and behavioral disorders among young people: Progress and possibilities. Washington, DC. National Academies Press.
International Society for Mental Health Online–Clinical Study Group. 2010. Assessing a person's suitability for online therapy. Marietta, GA. International Society for Mental Health Online–Clinical Study Group.
International Society for Mental Health Online & Psychiatric Society for Informatics. 2000. The suggested principles for the online provision of mental health services. Marietta, GA. International Society for Mental Health Online.
International Telecommunication Union. 2011. Key global telecom indicators for the world telecommunication service sector. Geneva. International Telecommunication Union.
International Telecommunication Union. 2011. The world in 2011: ITC facts and figures. Geneva. International Telecommunication Union.
International Telecommunication Union. 2015. ICT facts and figures. Geneva. International Telecommunication Union.
Islam MM, Topp L, Conigrave KM, von Beek I, Maher L, White A, Day CA. The reliability of sensitive information provided by injecting drug users in a clinical setting: Clinician-administered versus audio computer-assisted self-interviewing (ACASI). AIDS Care: Psychological and socio-medical aspects of AIDS/HIV. 2012;24(12):1496-1503.
Jamoom E, Beatty P, Bercovitz A, Woodell D, Palso MA, Rechtsteiner MS. 2012. Physician adoption of electronic health record systems: United States, 2011. NCHS data brief 98. Hyattsville, MD. National Center for Health Statistics.
Jansen W, Scarfone K. 2008. Guidelines on cell phone and PDA security: Recommendations of the National Institute of Standards and Technology. Washington, DC. U.S. Government Printing Office.
Jeyaraj A, Rottman JW, Lacity MC. A review of the predictors, linkages, and biases in IT innovation adoption research. Journal of Information Technology. 2006;21:1-23.
Jones BN, Colenda CC. Telemedicine and geriatric psychiatry. Psychiatric Services. 1997;48(6):783-785. [pmid: 9175185].
Jones S, Fox S. 2009. The social life of health information: Americans' pursuit of health takes place within a widening network of both online and offline sources. Washington, DC. Pew Research Center.
Joo NS, Kim BT. Mobile phone short message service messaging for behaviour modification in a community-based weight control programme in Korea. Journal of Telemedicine and Telecare. 2007;13:416-420. [pmid: 18078554].
Jordan ET, Ray EM, Johnson P, Evans WD. Text4Baby: Using text messaging to improve maternal and newborn health. Nursing for Womens Health. 2011;15:206-212.
Juzang I, Fortune T, Black S, Wright E, Bull S. A pilot programme using mobile phones for HIV prevention. Journal of Telemedicine and Telecare. 2011;17:150-153. [pmid: 21270049].
Kaltenthaler E, Parry G, Beverley C, Ferriter M. Computerised cognitive–behavioural therapy for depression: Systematic review. British Journal of Psychiatry. 2008;193:181-184. [pmid: 18757972].
Kaminer Y, Burleson JA, Goldston DB, Burke RH. Suicidal ideation among adolescents with alcohol use disorders during treatment and aftercare. The American Journal on Addictions. 2006;15:43-49. [pmid: 17182419].
Kaminer Y, Napolitano C. Dial for therapy: Aftercare for adolescent substance use disorders. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:1171-1174. [pmid: 15322422].
Kanz JE. Clinical-supervision.com: Issues in the provision of online supervision. Professional Psychology: Research and Practice. 2001;32:415-420.
Karlin BE, Ruzek JI, Chard KM, Eftekhari A, Monson CM, Hembree EA, Foa EB. Dissemination of evidence-based psychological treatments for posttraumatic stress disorder in the Veterans Health Administration. Journal of Traumatic Stress. 2010;23:663-673. [pmid: 21171126].
Kiluk BD, Sugarman DE, Nich C, Gibbons CJ, Martino S, Rounsaville BJ, Carroll KM. A methodological analysis of randomized clinical trials of computerassisted therapies for psychiatric disorders: Toward improved standards for an emerging field. American Journal of Psychiatry. 2011;168:790-799. [pmid: 21536689].
Kim SI, Kim HS. Effectiveness of mobile and internet intervention in patients with obese type 2 diabetes. International Journal of Medical Informatics. 2008;77:399-404. [pmid: 17881285].
King VL, Stoller KB, Kidorf M, Kindbom K, Hursh S, Brady T, Brooner RK. Assessing the effectiveness of an internet-based videoconferencing platform for delivering intensified substance abuse counseling. Journal of Substance Abuse Treatment. 2009;36:331-338. [pmid: 18775625].
Knealing TW, Wong CJ, Diemer KN, Hampton J, Silverman K. A randomized controlled trial of the therapeutic workplace for community methadone patients: A partial failure to engage. Experimental and Clinical Psychopharmacology. 2006;14:350-360. [pmid: 16893278].
Koch EF. The VA Maryland health care system's telemental health program. Psychological Services. 2012;9:203-205. [pmid: 22662735].
Kotz D, Avancha S, Baxi A. A privacy framework for mobile health and home-care systems. Proceedings of the first ACM workshop on security and privacy in medical and home-care systems. 2009:1-12. New York. Association for Computing Machinery.
Kuhn E, Greene C, Hoffman J, Nguyen T, Wald L, Schmidt J, Ruzek J. Preliminary evaluation of PTSD Coach, a smartphone app for post-traumatic stress symptoms. Military Medicine. 2014;179:12-18. [pmid: 24402979].
LaMendola WF. 1997. Telemental health services in the U.S. frontier areas. Letter to the Field No. 3. Boulder, CO. Western Interstate Commission for Higher Education.
Lazev A, Vidrine D, Arduino R, Gritz E. Increasing access to smoking cessation treatment in a low-income, HIV-positive population: The feasibility of using cellular telephones. Nicotine and Tobacco Research. 2004;6:281-286. [pmid: 15203801].
Lenhart A. 2009. Adults and social network websites. Washington, DC. Pew Research Center.
Lenhart A. 2009. Social networks grow: Friending mom and dad. Washington, DC. Pew Research Center.
Lenhart A. 2009. The democratization of online social networks. Washington, DC. Pew Research Center.
Leong KC, Chen WS, Leong KW, Mastura I, Mimi O, Sheikh MA, Teng CL. The use of text messaging to improve attendance in primary care: A randomized controlled trial. Family Practice. 2006;23:699-705. [pmid: 16916871].
Levine D, Madsen A, Wright E, Barar RE, Santelli J, Bull S. Formative research on MySpace: Online methods to engage hard-to-reach populations. Journal of Health Communication. 2011;16:448-454. [pmid: 21391040].
Lieberman DZ, Huang SW. A technological approach to reaching a hidden population of problem drinkers. Psychiatric Services. 2008;59:297-303. [pmid: 18308911].
Lim MSC, Hocking JS, Hellard ME, Aitken CK. SMS STI:A review of the uses of mobile phone text messaging in sexual health. International Journal of STD & AIDS. 2008;19:287-290. [pmid: 18482956].
Linehan MM. 1993. Cognitive–behavioral treatment of borderline personality disorder. New York. Guilford Press.
Lord S, Brevard J, Budman S. Connecting to young adults: An online social network survey of beliefs and attitudes associated with prescription opioid misuse among college students. Substance Use & Misuse. 2011;46:66-76. [pmid: 21190407].
Lubans DR, Morgan PJ, Callister R, Collins CE. Effects of integrating pedometers, parental materials, and e-mail support within an extracurricular school sport intervention. Journal of Adolescent Health. 2009;44:176-183. [pmid: 19167667].
Luxton DD, June JD, Kim JT. Technology-based suicide prevention: Current applications and future directions. Telemedicine Journal and e-Health: The Official Journal of the American Telemedicine Association. 2011;17:50-54. [pmid: 21214382].
Luxton DD, Sirotin AP, Mishkind MC. Safety of telemental healthcare delivered to clinically unsupervised settings: A systematic review. Journal of Telemedicine and eHealth. 2010;16(6):705-711.
Maheu MM, Gordon BL. Counseling and therapy on the Internet. Professional Psychology: Research and Practice. 2000;31:484-489.
Maheu M, McMenamin J, Pulier ML. 2013. Optimizing the use of technology in psychology with best practice principles. Koocher GP, Norcross JC, Greene BA, editors. Psychologists' desk reference. 3rd edition. New York. Oxford University Press Publication.
Maheu MM, Pulier ML, Roy S. 2013. Finding, evaluating and using smartphone applications. Koocher GP, Norcross JC, Greene BA, editors. Psychologists' desk reference. 3rd edition. New York. Oxford University Press.
Maheu MM, Pulier ML, Wilhelm FH, McMenamin JP, Brown-Connolly NE. 2004. The mental health professional and the new technologies: A handbook for practice today. Mahwah, NJ. Lawrence Erlbaum Associates.
Mallen MJ, Vogel DL, Rochlen AB. The practical aspects of online counseling: Ethics, training, technology, and competency. The Counseling Psychologist. 2005;33:776-818.
Mallen MJ, Vogel DL, Rochlen AB, Day SX. Online counseling: Reviewing the literature from a counseling psychology framework. The Counseling Psychologist. 2005;33:819-871.
Marrow CE, Hollyoake K, Hamer D, Kenrick C. Clinical supervision using video-conferencing technology: A reflective account. Journal of Nursing Management. 2002;10:275-282. [pmid: 12191073].
Marsch LA. 2011. August. Computer delivered psychosocial treatment for substance use disorders. Aklin WM, Onken L, editors. (Co-Chairs). Symposium on neurobiological and technological mechanisms to improve the efficacy and effectiveness of substance abuse treatment. Symposium conducted at the American Psychological Association Annual Meeting. Washington, DC.
Marsch LA. Technology-based interventions targeting substance use disorders and related issues: An editorial. Substance Use & Misuse. 2011;46:1-3. [pmid: 21190400].
Marsch LA, Bickel WK. Efficacy of computer-based HIV/AIDS education for injection drug users. American Journal of Health Behavior. 2004;28:316-327. [pmid: 15228968].
Marsch LA, Bickel WK, Badger GJ. Applying computer technology to substance abuse prevention science: Results of a preliminary examination. Journal of Child & Adolescent Substance Abuse. 2007;16:69-94.
Marsch LA, Grabinski MJ, Bickel WK, Desrosiers A, Guarino H, Muehlbach B, Acosta M. Computer-assisted HIV prevention for youth with substance use disorders. Substance Use & Misuse. 2011;46:46-56. [pmid: 21190405].
Marsch LA, Guarino H, Acosta M, Aponte-Melendez Y, Cleland C, Grabinski M, Edwards J. Web-based behavioral treatment for substance use disorders as a partial replacement of standard methadone maintenance treatment. Journal of Substance Abuse. 2013;46:43-51.
McAdams CR III, Wyatt KL. The regulation of technology-assisted distance counseling and supervision in the United States: An analysis of current extent, trends, and implications. Counselor Education and Supervision. 2010;49:179-192.
McCann IL, Pearlman LA. Vicarious traumatization: A framework for understanding the psychological effects of working with victims. Journal of Traumatic Stress. 1990;3:131-149.
McGinty KL, Saeed SA, Simmons SC, Yildirim Y. Telepsychiatry and e-mental health services: Potential for improving access to mental health care. Psychiatric Quarterly. 2006;77:335-342. [pmid: 16927161].
McGovern MP, Lambert-Harris C, Alterman AI, Xie H, Meier A. A randomized controlled trial comparing integrated cognitive behavioral therapy versus individual addiction counseling for co-occurring substance use and posttraumatic stress disorders. Journal of Dual Diagnosis. 2011;7:207-227. [pmid: 22383864].
McGurk SR, Twamley EW, Sitzer DI, McHugo GJ, Mueser KT. A meta-analysis of cognitive remediation in schizophrenia. American Journal of Psychiatry. 2007;164:1791-1802. [pmid: 18056233].
McKay JR, Lynch KG, Shepard DS, Pettinati HM. The effectiveness of telephone-based continuing care for alcohol and cocaine dependence: 24-month outcomes. Archives of General Psychiatry. 2005;62:199-207. [pmid: 15699297].
McKay JR, Lynch KG, Shepard DS, Ratichek S, Morrison R, Koppenhaver J, Pettinati HM. The effectiveness of telephone-based continuing care in the clinical management of alcohol and cocaine use disorders: 12-month outcomes. Journal of Consulting and Clinical Psychology. 2004;72:967-979. [pmid: 15612844].
McKinsey and Company, & U.S. National Information Infrastructure Advisory Council. 1995. Connecting K-12 students to the information superhighway. Palo Alto, CA. McKinsey and Co.
McTavish FM, Chih M-Y, Shah D, Gustafson DH. How patients recovering from alcoholism use a smartphone intervention. Journal of Dual Diagnosis. 2012;8(4):204-394.
Meites E, Thom DH. Telephone counseling improves smoking cessation rates. American Family Physician. 2007;75:651-652.
Mensinger JL, Diamond GS, Kaminer Y, Wintersteen MB. Adolescent and therapist perception of barriers to outpatient substance abuse treatment. American Journal of Addiction. Supplement 1. 2006;15:16-25.
Merz TA. Using cell/mobile phone SMS for therapeutic intervention. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:29-38. Springfield, IL. Charles C. Thomas Publishers.
Meyer BC, Clarke CA, Troke TM, Friedman LS. Essential telemedicine elements (tele-ments) for connecting the academic health center and remote community providers to enhance patient care. Academic Medicine. 2012;87:1032-1040. [pmid: 22722348].
Midkiff DM, Wyatt WJ. Ethical issues in the provision of online mental health services (etherapy). Journal of Technology in Human Services. 2008;26:310-332.
Miller NA, Najavits LM. Creating trauma-informed correctional care: A balance of goals and environment. European Journal of Psychotraumatology. 2012;3:17246.
Mills KL, Teesson M, Back SE, Brady KT, Baker AL, Hopwood S, Ewer PL. Integrated exposure-based therapy for co-occurring posttraumatic stress disorder and substance dependence: A randomized controlled trial. Journal of the American Medical Association. 2012;308:690-699. [pmid: 22893166].
Mohr DC. Telemental health: Reflections on how to move the field forward. Clinical Psychology: Science and Practice. 2009;16:343-347.
Mohr DC, Carmody T, Erickson L, Jin L, Leader J. Telephone-administered cognitive behavioral therapy for veterans served by community-based outpatient clinics. Journal of Consulting and Clinical Psychology. 2011;79:261-265. [pmid: 21299274].
Mohr DC, Siddique J, Ho J, Duffecy J, Jin L, Fokuo JK. Interest in behavioral and psychological treatments delivered face-to-face, by telephone, and by internet. Annals of Behavioral Medicine. 2010;40:89-98. [pmid: 20652466].
Molfenter T, Boyle M, Holloway D, Zwick J. Trends in telemedicine use in addiction treatment. Addiction Science & Clinical Practice. 2015;10:14. [pmid: 26016484].
Moore BA, Fazzino T, Garnet B, Cutter CJ, Barry DT. Computer-based interventions for drug use disorders: A systematic review. Journal of Substance Abuse Treatment. 2011;40:215-223. [pmid: 21185683].
Moore D, Guthmann D, Rogers N, Fraker S, Embree J. E-therapy as a means for addressing barriers to substance use disorder treatment for persons who are deaf. Journal of Sociology and Social Welfare. 2009;36:75-92.
Moreno MA, Vanderstoep A, Parks MR, Zimmerman FJ, Kurth A, Christakis DA. Reducing at-risk adolescents' display of risk behavior on a social networking web site: A randomized controlled pilot intervention trial. Archives of Pediatrics and Adolescent Medicine. 2009;163:35-41. [pmid: 19124701].
Muller I, Yardley L. Telephone-delivered cognitive behavioural therapy: A systematic review and meta-analysis. Journal of Telemedicine and Telecare. 2011;17:177-184. [pmid: 21357672].
Murphy L, MacFadden R, Mitchell D. Cybercounseling online: The development of a university-based training program for e-mail counseling. Journal of Technology in Human Services. 2008;26:447-469.
Murphy LJ, Mitchell DL. When writing helps to heal: E-mail as therapy. British Journal of Guidance & Counselling. 1998;26:21-32.
Nagal D, Anthony K. 2009. Ethical framework for the use of technology in mental health. Highlands, NJ. Online Therapy Institute.
Najavits LM. 2002. Seeking safety: A treatment manual for PTSD and substance abuse. New York. Guilford Press.
Najavits LM. 2009. Seeking safety: An implementation guide. Rubin A, Springer DW, editors. The clinician's guide to evidence-based practiceThe clinician. Hoboken, NJ. John Wiley and Sons.
Najavits LM, Norman SB, Kivlahan D, Kosten TR. Improving PTSD/substance abuse treatment in the VA: A survey of providers. The American Journal on Addictions. 2010;19:257-263. [pmid: 20525033].
National Association of Social Workers. 2008. Code of ethics. Washington, DC. National Association of Social Workers.
National Association of State Alcohol and Drug Abuse Directors. 2009. Telehealth in state substance use disorder (SUD) services. Washington DC. National Association of State Alcohol and Drug Abuse.
National Board for Certified Counselors and Center for Credentialing and Education. 2001. The practice of Internet counseling. Greensboro, NC. National Board for Certified Counselors.
National Institute for Health Research Clinical Research Network. Network support pays dividends for smoking cessation study. News from the network. 2011:6-7. Leeds, UK. National Institute for Health Research Clinical Research Network.
Naylor MR, Keefe FJ, Brigidi B, Naud S, Helzer JE. Therapeutic interactive voice response for chronic pain reduction and relapse prevention. Pain. 2008;134:335-345. [pmid: 18178011].
Network for the Improvement of Addiction Treatment. 2013. NIATx: Five principles. Madison, WI. Network for the Improvement of Addiction Treatment.
Neuner F, Schauer M, Klaschik C, Karunakara U, Elbert T. A comparison of narrative exposure therapy, supportive counseling, and psychoeducation for treating posttraumatic stress disorder in an African refugee settlement. Journal of Consulting and Clinical Psychology. 2004;72:579-587. [pmid: 15301642].
Neuner F, Schauer M, Roth WT, Elbert T. A narrative exposure treatment as intervention in a refugee camp: A case report. Behavioural and Cognitive Psychotherapy. 2002;30:205-210.
New Zealand Psychologists Board. 2011. Draft guidelines: Psychology services delivered via the Internet and other electronic media. Wellington, New Zealand. New Zealand Psychologists Board.
Newman MG, Consoli A, Taylor CB. Computers in assessment and cognitive behavioral treatment of clinical disorders: Anxiety as a case in point. Behavior Therapy. 1997;28:211-235.
Newman MG, Kenardy J, Herman S, Taylor CB. Comparison of palmtopcomputer-assisted brief cognitive–behavioral treatment to cognitive–behavioral treatment for panic disorder. Journal of Consulting and Clinical Psychology. 1997;65:178-183. [pmid: 9103747].
Newnham EA, Doyle EL, Sng AAH, Hooke GR, Page AC. Improving clinical outcomes in psychiatric care with touch-screen technology. Psychological Services. 2012;9:221-223. [pmid: 22662741].
Noar SM, Black HG, Pierce LB. Efficacy of computer technology-based HIV prevention interventions: A meta-analysis. AIDS. 2009;23:107-115. [pmid: 19050392].
Norman S. The use of telemedicine in psychiatry. Journal of Psychiatric and Mental Health Nursing. 2006;13:771-777. [pmid: 17087682].
Nundy S, Dick JJ, Chou C-H, Nocon RS, Chin MH, Peek ME. Mobile phone diabetes project led to improved glycemic control and net savings for Chicago plan participants. Health Affairs. 2014;33:265-272. [pmid: 24493770].
Obermayer JL, Riley WT, Asif O, Jean-Mary J. College smoking-cessation using cell phone text messaging. Journal of American College Health. 2004;53(2):71-78. [pmid: 15495883].
Office of National Drug Control Policy. 2010. National drug control strategy: 2010. Washington, DC. Office of National Drug Control Policy.
Office of National Drug Control Policy. 2013. National drug control strategy: 2013. Washington, DC. Office of National Drug Control Policy.
Ohio Psychological Association. 2010. Telepsychology guidelines. Columbus, OH. Ohio Psychological Association.
Ondersma SJ, Chase SK, Svikis DS, Schuster CR. Computer-based brief motivational intervention for perinatal drug use. Journal of Substance Abuse Treatment. 2005;28:305-312. [pmid: 15925264].
Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention a randomized trial with postpartum women. American Journal of Preventive Medicine. 2007;32:231-238. [pmid: 17236741].
Patrick K, Raab F, Adams AM, Dillon L, Zabinski M, Rock LC, Norman GJ. A text message-based intervention for weight loss: Randomized controlled trial. Journal of Medical Internet Research. 2009;11:e1. [pmid: 19141433].
Pedrero-Perez EJ, Rojo-Mota G, Ruiz-Sanchez de Leon JM, Llanero-Luque M, Puerta-Garcia C. Cognitive remediation in addictions treatment. Revista de Neurologia. 2011;52:163-172. [pmid: 21287493].
Pennebaker JW, Kiecolt-Glaser JK, Glaser R. Disclosure of traumas and immune function: Health implications for psychotherapy. Journal of Consulting and Clinical Psychology. 1988;56:239-245. [pmid: 3372832].
Pentland AS. Healthwear: Medical technology becomes wearable. Computer. 2004;37:4+42-4+49.
Pew Research Center. 2012. Internet adoption trend data: Adults. Washington, DC. Pew Research Center.
Pew Research Center. 2013. Health online 2013. Washington, DC. Pew Research Center.
Pew Research Center. 2014. The Web at 25 in the US. Washington, DC. Pew Research Center.
Pew Research Center. 2015. US smartphone use in 2015. Washington, DC. Pew Research Center.
Piette JD, Richardson C, Himle J, Duffy S, Torres T, Vogel M, Valenstein M. A randomized trial of telephonic counseling plus walking for depressed diabetes patients. Medical Care. 2011;49:641-648. [pmid: 21478777].
Pollard RQ, Dean RK, O'Hearn A, Haynes SL. Adapting health education material for deaf audiences. Rehabilitation Psychology. 2009;54:232-238. [pmid: 19469615].
Polosa R, Russo C, Di Maria A, Arcidiacono G, Morjaria JB, Piccillo GA. Feasibility of using e-mail counseling as part of a smoking-cessation program. Respiratory Care. 2009;54:1033-1039. [pmid: 19650944].
Postel MG, de Jong CA, de Haan HA. Does e-therapy for problem drinking reach hidden populations?. American Journal of Psychiatry. 2005;162:2393. [pmid: 16330613].
Primary Care Research Network. 2013. Case Studies: Network support pays dividends. London. Primary Care Research Network.
Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: Change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technology & Therapeutics. 2008;10:160-168. [pmid: 18473689].
Rabinowitz T, Murphy KM, Amour JL, Ricci MA, Caputo MP, Newhouse PA. Benefits of a telepsychiatry consultation service for rural nursing home residents. Journal of Telemedicine and eHealth. 2010;16(1):34-40.
Racine AD, Alderman EM, Avner JR. Effect of telephone calls from primary care practices on follow-up visits after pediatric emergency department visits: Evidence from the Pediatric Emergency Department Links to Primary Care (PEDLPC) randomized controlled trial. Archives of Pediatrics and Adolescent Medicine. 2009;163:505-511. [pmid: 19487605].
Ragusea AS, VandeCreek L. Suggestions for the ethical practice of online psychotherapy. Psychotherapy: Theory, Research, Practice, Training. 2003;40:94-102.
Ramo DE, Hall SM, Prochaska JJ. Reliability and validity of self-reported smoking in an anonymous online survey with young adults. Health Psychology. 2011;30:693-701. [pmid: 21574709].
Ramos-Ríos R, Mateos R, Lojo D, Conn DK, Patterson T. Telepsychogeriatrics: A new horizon in the care of mental health problems in the elderly. International Psychogeriatrics. 2012;24(11):1708-1724. [pmid: 22687259].
Recupero PR. Ethics of medical records and professional communications. Child and Adolescent Psychiatric Clinics of North America. 2008;17:37-51. viii. [pmid: 18036478].
Reese RJ, Conoley CW, Brossart DF. Effectiveness of telephone counseling: A field-based investigation. Journal of Counseling Psychology. 2002;49:233-242.
Reese RJ, Conoley CW, Brossart DF. The attractiveness of telephone counseling: An empirical investigation of client perceptions. Journal of Counseling & Development. 2006;84:54-60.
Regan S, Reyen M, Lockhart AC, Richards AE, Rigotti NA. An interactive voice response system to continue a hospital-based smoking cessation intervention after discharge. Nicotine and Tobacco Research. 2011;13:255-260. [pmid: 21330278].
Revere D, Dunbar PJ. Review of computer-generated outpatient health behavior interventions: Clinical encounters “in absentia”. Journal of the American Medical Informatics Association. 2001;8:62-79. [pmid: 11141513].
Rhodes SD, Hergenrather KC, Duncan J, Vissman AT, Miller C, Wilkin AM, Eng E. A pilot intervention utilizing Internet chat rooms to prevent HIV risk behaviors among men who have sex with men. Public Health Reports. Supplement 1. 2010;125:29-37. [pmid: 20408385].
Richens J, Copas A, Sadiq ST, Kingori P, McCarthy O, Jones V, Pakianathan M. A randomized controlled trial of computer-assisted interviewing in sexual health clinics. Sexually Transmitted Infections. 2010;86:310-314. [pmid: 20551234].
Rideout VJ, Foehr UG, Roberts DF. 2010. Generation M2 media in the lives of 8- to 18-year olds: A Kaiser Family Foundation study. Menlo Park, CA. The Henry J. Kaiser Family Foundation.
Riley W, Obermayer J, Jean-Mary J. Internet and mobile phone text messaging intervention for college smokers. Journal of American College Health. 2008;57:245-248. [pmid: 18809542].
Rimoldi G, Lewis P, Jampala C. 2012. Help at the hip: Increasing resiliency in high risk suicidal veterans through interactive text messaging. New York. Veterans Health Administration.
Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: A pragmatic randomized trial. Addiction. 2008;103:218-227. [pmid: 18199300].
Ritterband LM, Tate DF. The science of internet interventions: Introduction. Annals of Behavioral Medicine. 2009;38:1-3. [pmid: 19816750].
Rodgers A, Corbett T, Bramley D, Riddell T, Wills M, Lin RB, Jones M. Do u smoke after txt? Results of a randomised trial of smoking cessation using mobile phone text messaging. Tobacco Control. 2005;14:255-261. [pmid: 16046689].
Rodriguez MD, Favela J, Preciado A, Vizcaino A. Agent-based ambient intelligence for healthcare. AI Communications. 2005;18:201-216.
Roker D, Coleman J. Education and advice about illegal drugs: What do young people want?. Drugs-Education Prevention and Policy. 1997;4:53-64.
Rotondi AJ, Anderson CM, Haas GL, Eack SM, Spring MB, Ganguli R, Rosenstock J. Web-based psychoeducational intervention for persons with schizophrenia and their supporters: One-year outcomes. Psychiatric Services. 2010;61:1099-1105. [pmid: 21041348].
Royal Australian & New Zealand College of Psychiatrists. 2009. Telepsychiatry position statement (#44). Melbourne, Australia. Royal Australian & New Zealand College of Psychiatrists.
Royal Australian & New Zealand College of Psychiatrists. 2011. Telehealth: Brief guide to address practice issues. Melbourne, Australia. Royal Australian & New Zealand College of Psychiatrists.
Saitz R, Palfai TP, Freedner N, Winter MR, MacDonald A, Lu J, DeJong W. Screening and brief intervention online for college students: The iHealth study. Alcohol and Alcoholism. 2007;42:28-36. [pmid: 17130139].
Sands DZ. Help for physicians contemplating use of e-mail with patients. Journal of the American Medical Informatics Association. 2004;11:268-269. [pmid: 15252925].
Schinke S, Schwinn T, Cole K. Preventing alcohol abuse among early adolescents through family and computer-based interventions: Four-year outcomes and mediating variables. Journal of Developmental and Physical Disabilities. 2006;18:149-161. [pmid: 17215960].
Schinke SP, Schwinn TM, Di Noia J, Cole KC. Reducing the risks of alcohol use among urban youth: Three-year effects of a computer-based intervention with and without parent involvement. Journal of Studies on Alcohol. 2004;65:443-449. [pmid: 15376818].
Schinke SP, Schwinn TM, Ozanian AJ. Alcohol abuse prevention among high-risk youth: Computer-based intervention. Journal of Prevention & Intervention in the Community. 2005;29:117-130. [pmid: 16804562].
Screening for Mental Health Inc. 2012. National Depression Screening Day®: October 11, 2012. Wellesley Hills, MA. Screening for Mental Health, Inc.
Secure Telehealth. 2012. Medicaid reimburses for telepsychiatry in 40 states. Pittsburgh, PA. Secure Telehealth.
Segal ZV, Williams JMG, Teasdale JD. 2002. Mindfulness-based cognitive therapy for depression: A new approach to preventing relapse. New York. Guilford Press.
Selby P, van Mierlo T, Voci SC, Parent D, Cunningham JA. Online social and professional support for smokers trying to quit: An exploration of first time posts from 2562 members. Journal of Medical Internet Research. 2010;12:e34. [pmid: 20719739].
Selmi PM, Klein MH, Greist JH, Sorrell SP, Erdman HP. Computer-administered cognitive–behavioral therapy for depression. American Journal of Psychiatry. 1990;147:51-56. [pmid: 2403473].
Selmi PM, Klein MH, Greist JH, Sorrell SP, Erdman HP. Computer-administered therapy for depression. MD Computing. 1991;8:98-102. [pmid: 2038242].
Shapiro JR, Bauer S, Hamer RM, Kordy H, Ward D, Bulik CM. Use of text messaging for monitoring sugar-sweetened beverages, physical activity, and screen time in children: A pilot study. Journal of Nutrition Education and Behavior. 2008;40:385-391. [pmid: 18984496].
Sharp IR, Kobak KA, Osman DA. The use of videoconferencing with patients with psychosis: A review of the literature. Annals of General Psychiatry. 2011;10:14. [pmid: 21501496].
Shiffman S. Ecological momentary assessment (EMA) in studies of substance use. Psychological Assessment. 2009;21:486-497. [pmid: 19947783].
Shore JH, Brooks E, Anderson H, Bair B, Dailey N, Kaufmann LJ, Manson S. Characteristics of telemental health service use by American Indian veterans. Psychiatric Services. 2012;63(2):179-181. [pmid: 22302338].
Shore JH, Savin DM, Novins D, Manson SM. Cultural aspects of telepsychiatry. Journal of Telemedicine & Telecare. 2006;12(3):116-121. [pmid: 16638232].
Shore JH, Savin D, Orton H, Beals J, Manson SM. Diagnostic reliability of telepsychiatry in American Indian veterans. American Journal of Psychiatry. 2007;164(1):115-118. [pmid: 17202552].
Silverman K, Wong CJ, Grabinski MJ, Hampton J, Sylvest CE, Dillon EM, Wentland RD. A web-based therapeutic workplace for the treatment of drug addiction and chronic unemployment. Behavior Modification. 2005;29:417-463. [pmid: 15657415].
Simon GE, Ralston JD, Savarino J, Pabiniak C, Wentzel C, Operskalski BH. Randomized trial of depression follow-up care by online messaging. Journal of General Internal Medicine. 2011;26(7):698-704. [pmid: 21384219].
Simpson S, Morrow E. Using videoconferencing for conducting a therapeutic relationship. Anthony K, Nagel DM, Goss S, editors. The use of technology in mental health: Applications, ethics and practice. 2010:94-103. Springfield, IL. Charles C. Thomas Publishers.
Sloan DM, Gallagher MW, Feinstein BA, Lee DJ, Pruneau GM. Efficacy of telehealth treatments for posttraumatic stress-related symptoms: A meta-analysis. Cognitive Behaviour Therapy. 2011;40:111-125. [pmid: 21547778].
Smith A. 2010. Home broadband 2010. Washington, DC. Pew Research Center.
Smith B, Harms WD, Korda H, Rosen H, Davis J, Burres S. in press. Enhancing behavioral health treatment and crisis management through mobile ecological momentary assessment and SMS messaging. Health Informatics Journal.
Smith A, Rainie L, Zickuhr K. 2011. College students and technology. Washington, DC. Pew Internet and American Life Project.
Spek V, Nyklicek I, Cuijpers P, Pop V. Predictors of outcome of group and internet-based cognitive behavior therapy. Journal of Affective Disorders. 2008;105:137-145. [pmid: 17543392].
Stamm BH. Clinical applications of telehealth in mental health care. Professional Psychology: Research and Practice. 1998;29:536-542.
Stofle GS. Addiction treatment online. Behavioral Health Management. 2001;24:53-55.
Substance Abuse and Mental Health Services Administration. 2011. Addressing viral hepatitis in people with substance use disorders. Treatment Improvement Protocol (TIP) Series 53. HHS Publication No. (SMA) 11-4656. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Leading change: A plan for SAMHSA's roles and actions 2011-2014. HHS Publication No. (SMA) 11-4629. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Managing chronic pain in adults with or in recovery from substance use disorders. Treatment Improvement Protocol (TIP) Series 54. HHS Publication No. (SMA) 11-4661. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2012. SAMHSA's working definition of recovery: 10 guiding principles of recovery. HHS Publication No (PEP) 12-RECDEF. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Addressing the specific behavioral health needs of men. Treatment Improvement Protocol (TIP) Series 56. HHS Publication No. (SMA) 13-4736. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Behavioral health services for people who are homeless. Treatment Improvement Protocol (TIP) Series 55. HHS Publication No. (SMA) 13-4734. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Coming soon: GO2AID -A mobile app for disaster responders. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2014. Improving cultural competence. Treatment Improvement Protocol (TIP) Series 59. HHS Publication No SMA 14-4849. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2014. Leading change 2.0: Advancing the behavioral health of the nation 2015–2018. HHS Publication No (PEP) 14-LEADCHANGE2. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2014. Trauma-informed care in behavioral health services. Treatment Improvement Protocol (TIP) Series 57. HHS Publication No. (SMA) 14-4816. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned a). Behavioral health services: Building health, wellness, and quality of life for sustained recovery. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned b). Behavioral health services for American Indians and Alaska Natives. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned c). Managing anxiety symptoms in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned d). Recovery in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned e). Reintegration-related behavioral health issues in veterans and military families. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration, Trauma and Justice Strategic Initiative. 2012. SAMHSA's working definition of trauma and guidance for trauma-informed approach. [Draft]. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Suler J. Assessing a person's suitability for online therapy: The ISMHO clinical case study group. CyberPsychology & Behavior. 2001;4:675-679. [pmid: 11800174].
Tasker AP, Gibson L, Franklin V, Gregor P, Greene S. What is the frequency of symptomatic mild hypoglycemia in type 1 diabetes in the young?: Assessment by novel mobile phone technology and computer-based interviewing. Pediatric Diabetes. 2007;8:15-20. [pmid: 17341287].
Tate DF. A series of studies examining internet treatment of obesity to inform internet interventions for substance use and misuse. Substance Use & Misuse. 2011;46:57-65. [pmid: 21190406].
Tate DF, Finkelstein EA, Khavjou O, Gustafson A. Cost effectiveness of Internet interventions: Review and recommendations. Annals of Behavioral Medicine. 2009;38:40-45. [pmid: 19834778].
Tate DF, Zabinski MF. Computer and internet applications for psychological treatment: Update for clinicians. Journal of Clinical Psychology. 2004;60:209-220. [pmid: 14724928].
Taylor CB, Luce KH. Computer- and internet-based psychotherapy interventions. Current Directions in Psychological Science. 2003;12:18-22.
Te Poel F, Bolman C, Reubsaet A, de Vries H. Efficacy of a single computer-tailored e-mail for smoking cessation: Results after 6 months. Health Education Research. 2009;24:930-940. [pmid: 19574405].
Titov N, Andrews G, Robinson E, Schwencke G, Johnston L, Solley K, Choi I. Clinician-assisted internet-based treatment is effective for generalized anxiety disorder: Randomized controlled trial. Australian and New Zealand Journal of Psychiatry. 2009;43:905-912.
Treatment Research Institute. 2010. Integrating appropriate services for substance use conditions in health care settings: An issue brief on lessons learned and challenges ahead. Forum on Integration: Collaborative for States. Philadelphia. Treatment Research Institute.
Tse MM, Choi KC, Leung RS. E-health for older people: The use of technology in health promotion. Cyberpsychology and Behavior. 2008;11:475-479. [pmid: 18721097].
U.S. Department of Health and Human Services. 2006. HIPAA security guidance. Washington, DC. U.S. Department of Health and Human Services.
U.S. Department of Health and Human Services, Centers for Medicare and Medicaid Services. 2012. Telehealth services. Rural health fact sheets series (Rep. No. ICN 901705). Washington, DC. U.S. Department of Health and Human Services.
U.S. Department of Health and Human Services, Centers for Medicare and Medicaid Services. 2013. Expansion of Medicare telehealth services for calendar year (CY) 2013. MLN Matters (Rep. No. MM7900 Revised). Washington, DC. U.S. Department of Health and Human Services.
U.S. Department of Health and Human Services, Office of the Secretary. 2013. Modifications to the HIPAA privacy, security, enforcement, and breach notification rules under the Health Information Technology for Economic and Clinical Health Act and the Genetic Information Nondiscrimination Act; Other modifications to the HIPAA rules; Final rule. Rockville, MD. U.S. Department of Health and Human Services.
U.S. Food and Drug Administration. 2011. Mobile medical applications. Silver Spring MD. U.S. Food and Drug Administration.
U.S. Food and Drug Administration. 2014. Examples of mobile apps for which the FDA will exercise enforcement discretion. Silver Spring MD. U.S. Food and Drug Administration.
U.S. Food and Drug Administration Center for Devices and Radiological Health & Center for Biologics Evaluation and Research. 2013. Mobile medical applications: Guidance for industry and Food and Drug Administration staff. Silver Spring, MD. U.S. Food and Drug Administration, Center for Devices and Radiological Health & Center for Biologics Evaluation and Research.
Vaca FE, Winn D, Anderson CL, Kim D, Arcila M. Six-month follow-up of computerized alcohol screening, brief intervention, and referral to treatment in the emergency department. Substance Abuse. 2011;32:144-152. [pmid: 21660874].
Vaccaro N, Lambie GW. Computer-based counselor-in-training supervision: Ethical and practical implications for counselor educators and supervisors. Counselor Education and Supervision. 2007;47:46-57.
Valentine PV, Smith TE. Evaluating Traumatic Incident Reduction (TIR) therapy with female inmates: A randomized controlled clinical trial. Research on Social Work Practice. 2001;11(1):40-52.
Vernmark K, Lenndin J, Bjärehed J, Carlsson M, Karlsson J, Oberg J, Andersson G. Internet administered guided self-help versus individualized e-mail therapy: A randomized trial of two versions of CBT for major depression. Behaviour Research and Therapy. 2010;48(5):368-376. [pmid: 20152960].
Vilella A, Bayas JM, Diaz MT, Guinovart C, Diez C, Simó D, Cerezo J. The role of mobile phones in improving vaccination rates in travelers. Preventive Medicine. 2004;38:503-509. [pmid: 15020186].
Walters ST, Miller E, Chiauzzi E. Wired for wellness: e-Interventions for addressing college drinking. Journal of Substance Abuse Treatment. 2005;29:139-145. [pmid: 16135342].
Wantland DJ, Portillo CJ, Holzemer WL, Slaughter R, McGhee EM. The effectiveness of web-based vs. non-web-based interventions: A meta-analysis of behavioral change outcomes. Journal of Medical Internet Research. 2004;6:e40. [pmid: 15631964].
Watson A, Bickmore T, Cange A, Kulshreshtha A, Kvedar J. An internet-based virtual coach to promote physical activity adherence in overweight adults: Randomized controlled trial. Journal of Medical Internet Research. 2012;14:e1. [pmid: 22281837].
Webb TL, Joseph J, Yardley L, Michie S. Using the internet to promote health behavior change: A systematic review and meta-analysis of the impact of theoretical basis, use of behavior change techniques, and mode of delivery on efficacy. Journal of Medical Internet Research. 2010;12:e4. [pmid: 20164043].
Wei J, Hollin I, Kachnowski S. A review of the use of mobile phone text messaging in clinical and healthy behavior interventions. Journal of Telemedicine and Telecare. 2011;17:41-48. [pmid: 21097565].
Weingardt KR, Cucciare MA, Bellotti C, Lai WP. A randomized trial comparing two models of web-based training in cognitive–behavioral therapy for substance abuse counselors. Journal of Substance Abuse Treatment. 2009;37:219-227. [pmid: 19339136].
Weingardt KR, Villafranca SW, Levin C. Technology-based training in cognitive behavioral therapy for substance abuse counselors. Substance Abuse. 2006;27:19-25. [pmid: 17135177].
Weiser M. The computer for the 21st-century. Scientific American. 1991;265:94-104.
Weitzel JA, Bernhardt JM, Usdan S, Mays D, Glanz K. Using wireless handheld computers and tailored text messaging to reduce negative consequences of drinking alcohol. Journal of Studies on Alcohol and Drugs. 2007;68:534-537. [pmid: 17568957].
White A, Kavanagh D, Stallman H, Klein B, Kay-Lambkin F, Proudfoot J, Young R. Online alcohol interventions: A systematic review. Journal of Medical Internet Research. 2010;12:e62. [pmid: 21169175].
Whittaker R, Borland R, Bullen C, Lin RB, McRobbie H, Rodgers A. 2009. Mobile phone-based interventions for smoking cessation. Cochrane Database System Review. CD006611.
Winkler M, Flanagin A, Chi-Lum B, White J, Andrews K, Kennett R, DeAngelis C, Musacchio R. Guidelines for medical and health information sites on the internet. Journal of the American Medical Association. 2000;283(12):1600-1606.
Wisdom JP, Ford II JH, McCarty D. The use of health information technology in publicly-funded U. S. substance abuse treatment agencies. Contemporary Drug Problems: An Interdisciplinary Quarterly. 2010;37:315-339.
Wise PH, Dowlatshahi DC, Farrant S, Fromson S, Meadows KA. Effect of computer-based learning on diabetes knowledge and control. Diabetes Care. 1986;9:504-508. [pmid: 3533475].
Wood JAV, Miller TW, Hargrove DS. Clinical supervision in rural settings: A telehealth model. Professional Psychology: Research and Practice. 2005;36:173-179.
Yellowlees P, Burke MM, Marks SL, Hilty DM, Shore JH. Emergency telepsychiatry. Journal of Telemedicine and Telecare. 2008;14:277-281. [pmid: 18776070].