# Appendix A - Bibliography

Agut, H.; Aubin, J.T.; Ingrand, D.; Blanc, S.; Clayton, A.L.; Chantler, S.M.; and Huraux, J.M. (1990). Simplified test for detecting resistance of herpes simplex virus to acyclovir. Journal of Medical Virology.
Alexander-Rodriguez, T., and Vermund, S.H. (1987). Gonorrhea and syphilis in incarcerated urban adolescents: Prevalence and physical signs. Pediatrics.
American Academy of Pediatrics. (1991). Report of the Committee on Infectious Diseases. 22d ed. Chicago: American Academy of Pediatrics.
American Lung Association, Medical Section. (1992). Control of tuberculosis in the United States. American Review of Respiratory Disease.
American Public Health Association. (1990). Viral hepatitis B. In: Benenson, A.S., ed.
[no author]. (1990). Anonymous HIV testing. Lancet.
Barbacci, M.B.; Dalabetta, G.A.; Repke, J.T.; Talbot, B.L.; Charache, P.; Polk, B.F.; and Chaisson, R.E. (1990). Human immunodeficiency virus infection in women attending an inner-city prenatal clinic: Ineffectiveness of targeted screening. Sexually Transmitted Diseases.
Barnes, P.F.; Bloch, A.B.; Davidson, P.T.; and Snider, D.E. (1991). Tuberculosis in patients with human immunodeficiency virus infection. New England Journal of Medicine.
Battjes, R.J.; Pickens, R.W.; and Amsel, Z. (1989). Introduction of HIV infection among intravenous drug abusers in low prevalence areas. Journal of. Acquired Immune Deficiency Syndromes.
Bell, J.; Batey, R.G.; Farrell, G.C.; Crewe, E.B.; Cunningham, A.I.; and Byth, K. (1990). Hepatitis C virus in intravenous drug users. Medical Journal of Australia.
Benenson, A.S., ed. (1990). Control of Communicable Diseases in Man. 15th ed. Washington, DC: American Public Health Association.
Billstein, S.A., and Mattaliano, V.J. (1990). The "nuisance" sexually transmitted diseases: Molluscum contagiosum, scabies, and crab lice. Sexually Transmitted Diseases.
Binkin, N.J., and Koplan, J.P. (1989). The high cost and low efficacy of weekly viral cultures for pregnant women with recurrent genital herpes: A reappraisal. Medical Decision Making.
Borst, M.; Butterworth, C.E.; Baker, V.; Kuykendall, K.; Gore, H.; Soong, S.; and Hatch, K.D. (1991). Human papillomavirus screening for women with atypical Papanicolaou smears. Journal of Reproductive Medicine.
Brandeau, M.L.; Owens, D.K.; Sox, C.H.; and Wachter, R.M. (1992). Screening women of childbearing age for human immunodeficiency virus. A cost-benefit analysis. Archives of Internal Medicine.
Brickner, P.W.; Torres, R.A.; Barnes, M.; Newman, R.G.; Des Jarlais, D.C.; Whalen, D.P.; and Rogers, D.E. (1989). Recommendations for control and prevention of human immunodeficiency virus (HIV) infection in intravenous drug users. Annals of Internal Medicine.
Brooner, R.K.; Bigelow, G.E.; Strain, E.; and Schmidt, C.W. (1990). Intravenous drug abusers with antisocial personality disorder: Increased HIV risk behavior. Drug and Alcohol Dependence.
Brown, L.S.; Chu, A.; Allain, J.P.; Lee, H.; Cerney, M.; and Nemoto, T. (1991). Seroepidemiology and clinical aspects of human T-cell lymphotropic virus type I/II infection in a cohort of intravenous drug users in New York City. New York State Journal of Medicine.
Brown, Z.A.; Benedetti, J.; Ashley, R.; Burchett, S.; Selke, S.; Berry, S.; Bontver, L.A.; and Corey, L. (1991). Neonatal herpes simplex virus infection in relation to asymptomatic maternal infection at the time of labor. New England Journal of Medicine.
Brudney, K., and Dobkin, J. (1991). Resurgent tuberculosis in New York City: Human immunodeficiency virus, homelessness, and the decline of tuberculosis control programs. American Review of Respiratory Disease.
Byrne, R.E.; Laska, S.; Bell, M.; Larson, D.; Phillips, J.; and Todd, J. (1992). Evaluation of a Treponema pallidum Western Immunoblot Assay as a confirmatory test for syphilis. Journal of Clinical Microbiology.
Cartter, M.L.; Petersen, L.R.; Savage, R.B.; Donagher, J.; and Hadler, J.L. (1990). Providing HIV counseling and testing services in methadone maintenance programs. AIDS.
Caussy, D.; Weiss, S.H.; Blattner, W.A.; French, J.; Cantor, K.P.; Ginzburg, H.; Altman, R.; and Goedert, J.J. (1990). Exposure factors for HIV-1 infection among heterosexual drug abusers in New Jersey treatment programs. AIDS Research and Human Retroviruses.
Celentano, C.C.; Vlahov, D.; Cohn, S.; Anthony, J.C.; Solomon, L.; and Nelson, K.E. (1991). Risk factors for shooting gallery use and cessation among intravenous drug users. American Journal of Public Health.
Centers for Disease Control. (1987). Public Health Service guidelines for counseling and antibody testing to prevent HIV infection and AIDS. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1987). Recommendations for prevention of HIV transmission in health-care settings. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1987). Revision of the CDC surveillance case definition of acquired immunodeficiency syndrome. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1988). Changing patterns of groups at high risk for hepatitis B in the United States. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (June 24, 1988). Update. Universal precautions for prevention of transmission of human immunodeficiency virus, hepatitis B virus, and other bloodborne pathogens in health-care settings. Morbidity and Mortality Weekly Report.
Centers for Disease Control. A Comprehensive Program to Prevent HIV Transmission, Fiscal Year 1989 Operating Plan.
Centers for Disease Control. (1989). Prevention of perinatal transmission of hepatitis B virus: Prenatal screening of all pregnant women for hepatitis B antigen. Recommendations of the Immunizations Practices Advisory Committee. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1989). Counseling and testing intravenous drug users for HIV infection. Morbidity and Mortality Weekly Report.
Centers for Disease Control. Immunization Practices Advisory Committee. (1989). General recommendations on immunization. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1989). Guidelines for prevention of transmission of human immunodeficiency virus and hepatitis B virus to health-care and public-safety workers.
Centers for Disease Control. (1989). Sexually transmitted diseases: Treatment guidelines. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1989). A strategic plan for the elimination of tuberculosis in the United States. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1989). Tuberculosis and human immunodeficiency virus infection: A statement by the Advisory Committee for Elimination of Tuberculosis. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1990). Guidelines for preventing the transmission of tuberculosis in health-care settings, with special focus on HIV-related issues. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1990).
Centers for Disease Control. (1990). Mandatory reporting of infectious diseases by clinicians and mandatory reporting of occupational diseases by clinicians. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1990). Protection against viral hepatitis: Recommendations of the Immunization Practices Advisory Committee. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1990). Screening for tuberculosis and tuberculosis infection in high-risk populations: Recommendations of the Advisory Committee for the Elimination of Tuberculosis. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1990). Surveillance for AIDS and HIV infection among black and Hispanic children and women of childbearing age, 1981-1989. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1990). Update: Tuberculosis elimination-United States. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1990). The use of preventive therapy for tuberculosis infection in the United States. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1991). Alternative case-finding methods in a crack-related syphilis epidemic in Philadelphia. Morbidity and Mortality Weekly Report.
Centers for Disease Control and American Thoracic Society. (1991).
Centers for Disease Control. (1991). Hepatitis B virus: A comprehensive strategy for eliminating transmission in the United States through universal childhood vaccination: Recommendations of the Immunization Practices Advisory Committee. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1991). HIV/AIDS Surveillance, October.
Centers for Disease Control. (1991). Nosocomial transmission of multi-drug resistant tuberculosis among HIV-infected persons-Florida and New York, 1988-1991. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1991). Purified protein derivative (PPD)-Tuberculin anergy and HIV infection: Guidelines for anergy testing and management of anergic persons at risk of tuberculosis. Morbidity and Mortality Weekly Report.
Centers for Disease Control. Sexually Transmitted Diseases: Clinical Practice Guidelines, May 1991. (1993 Sexually Transmitted Diseases Treatment Guidelines is in press.).
Centers for Disease Control. (1991). Transmission of multidrug-resistant tuberculosis from an HIV-positive client in a residential substance-abuse treatment facility-Michigan. Morbidity and Mortality Weekly Report.
Centers for Disease Control. (1991 (excerpts)). Update on Adult Immunization: Recommendations of the Immunization Practices Advisory Committee (ACIP).
Centers for Disease Control. (1992). Update: Acquired Immunodeficiency Syndrome-United States, 1991. Morbidity and Mortality Weekly Report.
Centers for Disease Control. What Drug Treatment Centers Can Do To Prevent Tuberculosis. Atlanta, GA: U.S. Department of Health and Human Services, n.d.
Centers for Disease Control and Prevention. (1993). Division of STD/HIV Prevention 1992 Annual Report. Atlanta, GA: Centers for Disease Control and Prevention.
Centers for Disease Control and Prevention. (1992). 1993 Revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults. Morbidity and Mortality Weekly Report.
Centers for Disease Control and Prevention. (1993). Initial therapy for tuberculosis in the era of multidrug resistance. Recommendations of the Advisory Council for the Elimination of Tuberculosis. Morbidity and Mortality Weekly Report.
Centers for Disease Control and Prevention. (1993). Recommendations for HIV testing services for inpatients and outpatients in acute-care hospital settings and technical guidance on HIV counseling. Morbidity and Mortality Weekly Report.
[Chamberland, M.E.]. (1989 (correspondence)). Unusual modes of HIV transmission. New England Journal of Medicine.
Chambers, H.F.; Korzeniowski, O.M.; and Sande, M.A.; with the National Collaborative Endocarditis Study Group. (1983). Staphylococcus aureus endocarditis: Clinical manifestations in addicts and nonaddicts. Medicine.
Chambers, H.F.; Morris, D.L.; Tauber, M.G.; and Modin, G. (1987). Cocaine use and the risk for endocarditis in intravenous drug users. Annals of Internal Medicine.
Chandrasekar, P.H.; Mounari, Molinari J.A.; and Kruse, J.A. (1990). Risk factors for human immunodeficiency virus infection among parenteral drug abusers in a low-prevalence area. Southern Medical Journal.
Chiang, W., and Goldfrank, L. (1990). The medical complications of drug abuse. Medical Journal of Australia.
Chu, A.; Brown, L.S.; Banks, S.; Nemoto, T.; and Primm, B.J. (1990). Intravenous heroin use: Its association with HIV infection in patients in methadone treatment. In.
Chung, D.C.; Ko, Y.C.; Chen, C.J.; Chen, E.R.; Wu, C.C.; and Wu, P.S. (1989). Seroepidemiology of hepatitis B virus, hepatitis D virus, and human immunodeficiency virus infections among parenteral drug abusers in southern Taiwan. Journal of Medical Virology.
Cohen, P.T.; Sande, M.A.; and Volberding, P.A. (1990). The AIDS Knowledge Base. Waltham, MA: The Medical Publishing Group.
Costa, S.; Rotola, A.; Terzano, P.; Poggi, M.G.; Di Luca, D.; Aurelian, L.; Cassai, E.; and Orlandi, C. (1990). Search for herpes simplex virus 2 and human papillomavirus genetic expression in vulvar neoplasia. Journal of Reproductive Medicine.
Crystal, S., and Weiss, S.H. (1990). Diagnosis and treatment of HIV illness in the elderly. Internal Medicine for the Specialist.
DeFelice, J.; Rumsfield, J.; Bernstein, J.E.; and Roshal, J.Y. (1989). Clinical evaluation of an after-pediculicide nit removal system. International Journal of Dermatology.
DePhilippis, D.; Metzger, D.S.; Woody, G.E.; and Navaline, H.A. (1992). Attitudes toward mandatory human immunodeficiency virus testing and contact tracing. A survey of intravenous drug users in treatment. Journal of Substance Abuse Treatment.
Deschenes, J.; Seamone, C.; and Baines, M. (1990). The ocular manifestations of sexually transmitted diseases. Canadian Journal of Ophthalmology.
Des Jarlais, D.C.; Friedman, S.R.; and Casriel, C. (1990). Target groups for preventing AIDS among intravenous drug users: The "hard" data studies. . Journal of Consulting and Clinical Psychology.
Devenyi, Devenvi, P., and McDonough, M.A. (1988 (correspondence)). Cocaine abuse and endocarditis. Annals of Internal Medicine.
Donahue, J.G.; Nelson, K.E.; Munoz, A.; Zlahov, D.; Rennie, L.L.; Taylor, E.L.; Saah, A.I.; Cone, F.; Odaka, N.J.; and Farzadegan, H. (1991). Antibody to hepatitis C virus among cardiac surgery patients, homosexual men and intravenous drug users in Baltimore, Maryland. American Journal of Epidemiology.
Dooley, S.W.; Villarino, M.E.; Lawrence, M.; Salinas, L.; Amil, S.; Rullan, J.V.; Jarvis, W.R.; Bloch, A.B.; and Cauthen, G.M. (1992). Nosocomial transmissions of tuberculosis in a hospital unit for HIV-infected patients. . Journal of the American Medical Association.
Doss, S.; Powell, C.A.; and Miller, A.J. (1991). Phenothrin lotion, the latest recruit in the battle against headlice: The results of two controlled comparative studies. Journal of the Royal Society of Health.
Dworkin, B.M.; Stahl, R.E.; Giardina, M.A.; Wormser, G.P.; Weiss, L.; Jankowski, R.; and Rosenthal, W.S. (1987). The liver in acquired immune deficiency syndrome: Emphasis on patients with intravenous drug abuse. American Journal of Gastroenterology.
Embretson, J.; Zupancic, M.; Ribas, J.L.; Burke, A.; Racz, P.; Tenner-Racz, K.; and Haase, A.T. (1993). Massive covert infection of helper T lymphocytes and macrophages by HIV during the incubation period of AIDS. Nature.
Farley, T.A.; Hadler, J.L.; and Gunn, R.A. (1990). The syphilis epidemic in Connecticut: Relationship to drug use and prostitution. Sexually Transmitted Diseases.
Farnes, S.W., and Setness, P.A. (1990). Serologic tests for syphilis. Postgraduate Medicine.
Farrell, M.; Battersby, M.; and Strang, J. (1990). Screening for hepatitis B and vaccination of injecting drug users in NHS drug treatment services. British Journal of Addiction.
Ferguson, K.J.; Stapleton, J.T.; and Helms, C.M. Physicians' effectiveness in assessing risk for human immunodeficiency virus infection Archives of Internal Medicine 151:561-564 1991View this and related citations using
Fischl, M.A.; Uttamchandani, R.B.; Daikos, G.L.; Poblete, R.B.; Moreno, J.N.; Reyes, R.R.; Boota, A.M.; Thompson, L.M.; Cleary, T.J.; and Lai, S. (1992). An outbreak of tuberculosis caused by multiple-drug-resistant tubercle bacilli among patients with HIV infection. Annals of Internal Medicine.
Friedman, L. (1989 1988. (correspondence)). Tuberculosis screening in alcoholics and drug addicts. American Review of Respiratory Disease.
Friedman, L.N.; Sullivan, G.M.; Bevilaqua, R.P.; and Loscos, R. (1987). Tuberculosis screening in alcoholics and drug addicts. American Review of Respiratory Disease.
Fuchs, D.; Unterweger, B.; Hausen, A.; Reibnegger, G.; Werner, E.R.; Hengster, P.; Hinterhuber, H.; Dierich, M.P.; Washter, H.; Blattner, W.A.; and Weiss, S.H. (1988). Anti-HIV-1 antibodies, anti-HTLV-I antibodies and neopterin levels in parenteral drug addicts in the Austrian Tyrol. Journal of Acquired Immune Deficiency Syndromes.
Gibert, C.L. Indicators of and Screening for Infectious Diseases in Substance Abusers: Bacteremia, Septicemia, Endocarditis, and Fungal Infections.
Ginzburg, H.M.; MacDonald, M.G.; and Glass, J.W. (1987). AIDS, HTLV-III diseases, minorities, and intravenous drug abuse. Advances in Alcohol and Substance Abuse.
Glatt, A.E.; Stoffer, H.R.; Forlenza, S.; and Altieri, R.H. (1991). High-titer positive nontreponemal tests with negative specific treponemal serology in patients with HIV infection and/or intravenous substance use. Journal of Acquired Immune Deficiency Syndromes.
Gorbach, S.L.; Bartlett, J.G.; and Blacklow, N.R. (1992). Infectious Diseases.
Gostin, L. (1990). A decade of a maturing epidemic: An assessment and directions for future public policy. American. Journal of Law and Medicine.
Gostin, L.O. (1989). Public health strategies for confronting AIDS. Journal of the American Medical Association.
Gourevitch, M.N.; Selwyn, P.A.; Davenny, K.; Buono, D.; Schoenbaum, E.E.; Klein, R.S.; and Friedland, G.H. Effects of HIV infection on the serologic manifestations and response to treatment of syphilis in intravenous drug users Annals of Internal Medicine 118 5 350 355 1993View this and related citations using8094280
Graham, N.M.; Nelson, K.E.; Solomon, L.; Bonds, M.; Rizzo, R.T.; Scavotto, J.; Astemborski, J.; and Vlahov, D. Prevalence of tuberculin positivity and skin test anergy in HIV-1-seropositive and -seronegative intravenous drug users Journal of the American Medical Association 267 3 369 373 1992View this and related citations using1727959
Green, J.; Monteiro, E.; and Gibson, P. Detection of human papillomavirus DNA in semen from patients with intrarectal penile warts Genitourinary Medicine 65:357-360 1989View this and related citations using
Gregory, P.B. (1989). Chronic hepatitis. In.
Gregory, P.B. (1990). Acute hepatitis. In.
The Alan Guttmacher Institute. (1993). Testing Positive: Sexually Transmitted Disease and the Public Health Response by P. Donovan. New York: The Alan Guttmacher Institute.
Guyot, D.R.; Manoli, A.; and Kling, G.A. Pyogenic sacroiliitis in IV drug abusers American Journal of Roentgenology 149:1209-1211 1987View this and related citations using
Handsfield, H.H.; Rice, R.J.; Roberts, M.C.; and Holmes, K.K. Localized outbreak of penicillinase-producing Neisseria gonorrhoeae: Paradigm for introduction and spread of gonorrhea in a community Journal of the American Medical Association 261 16 2357 2361 1989View this and related citations using2495372
Harris, R.E.; Langrod, J.; Herbert, J.R.; Lowinson, J.; Zang, E.; and Wynder, E.L. Changes in AIDS risk behavior among intravenous drug abusers in New York City New York State Journal of Medicine 90 3 123 126 1990View this and related citations using2314716
Hart, G.J.; Carvell, A.L.M.; Woodward, N.; Johnson, A.M.; Williams, P.; and Parry, J.V. 1989View this and related citations using
Haverkos, H.W. (1990 1991). Infectious diseases and drug abuse: Prevention and treatment in the drug abuse treatment system. Journal of Infectious Diseases.
Hecht, F., and Soloway, B. (1991). Laboratory tests for monitoring HIV infection. AIDS Clinical Care.
Hibbs, J.R., and Gunn, R.A. (1991). Public health intervention in a cocaine-related syphilis outbreak. American Journal of Public Health.
Higgins, D.L.; Galavotti, C.; O'Reilly, K.R.; Schnell, D.J.; Moore, M.; Rugg, D.L.; and Johnson, R. Evidence for the effects of HIV antibody counseling and testing on risk behaviors Journal of the American Medical Association 266 17 2419 2429 1991View this and related citations using1920748
Hook, E.W., III, and Marra, C.M. (1992). Acquired syphilis in adults. New England Journal of Medicine.
Howard, L.C.; Hawkins, D.A.; Marwood, R.; Shanson, D.C.; and Gazzarde, B.G. Transmission of human immunodeficiency virus by heterosexual contact with reference to antenatal screening British Journal of Obstetrics and Gynaecology 96:135-139 1989View this and related citations using
Hubbard, R.L.; Marsden, M.E.; Cavanaugh, E.; Rachal, J.V.; and Ginzburg, H.M. Role of drug-abuse treatment in limiting the spread of AIDS Reviews of Infectious Diseases 10 2 377 384 1988View this and related citations using3259712
Huovo, Nuovo G.J., and Nuovo J. (1991). Should family physicians test for human papillomavirus infection? An opposing view. Journal of Family Practice.
Hutchinson, C.M.; Rompalo, A.M.; Reichart, C.A.; and Hook, E.M. Characteristics of patients with syphilis attending Baltimore STD clinics: Multiple high-risk subgroups and interactions with human immunodeficiency virus infection Archives of Internal Medicine 151:511-516 1990 1991View this and related citations using
Iseman, M.D. (1992). A leap of faith. What can we do to curtail intrainstitutional transmission of tuberculosis?. Annals of Internal Medicine.
Jacobson, M.A; Gellermann, H.; and Chambers, H. Staphylococcus aureus bacteremia and recurrent staphylococcal infection in patients with acquired immunodeficiency syndrome and AIDS-related complex American Journal of Medicine 85:172-176 1988View this and related citations using
Jaffe, H.W., and Musher, D.M. (1990). Management of the reactive syphilis serology. In: Holmes, K.; Mardh, P.; Sparling, P.; Wiesner, P.; Cates, W., Jr.; Lemon, S.; and Stamm, W. eds.
Jenkins, S.C., and Simmons, P.S. (1990). Survey of genitourinary organisms in a population of sexually active adolescent males admitted to a chemical dependency unit. Journal of Adolescent Health Care.
Jewell, M.E., and Jewell, G.S. (1989). How to assess the risk of HIV exposure. American Family Physician.
Jones, T.S.; Allen, D.M.; Onorato, I.M.; Petersen, L.R.; Dondero, T.J.; and Pappaioanou, M. HIV seroprevalence surveys in drug treatment centers Public Health Reports 105 2 125 130 1990View this and related citations using2108456
Jordan, T.J.; Lewit, E.M.; Montgomery, R.L.; and Reichman, L.B. Isoniazid as preventive therapy in HIV-infected intravenous drug abusers: A decision analysis Journal of the American Medical Association 265 22 2987 2991 1991View this and related citations using2033771
Kane, M.A.; Alter, M.J.; Hadler, S.C.; and Margolis, H.S. Hepatitis B infection in the United States: Recent trends and future strategies for control American Journal of Medicine 87 (Supplement 3A):3A-11S-3A-13S 1989View this and related citations using
Karan, L.D. (1990). Primary care for AIDS and chemical dependence. Western Journal of Medicine.
Kellokoski, J.; Syrjanen, S.; Kataja, V.; Yliskoski, M.; and Syrjanen, K. (1990). Acetowhite staining and its significance in diagnosis of oral mucosal lesions in women with genital HPV infections. Journal of Oral Pathology and Medicine.
Khabbaz, R.F.; Douglas, J.M.; Judson, F.N.; Spiegel, R.A.; St. Louis, M.E.; Whittington, W.; Hartley, T.M.; Lairmore, M.; and Kaplan, J.E. (1990). Seroprevalence of human T-lymphotropic virus type I or II in sexually transmitted disease clinic patients in the USA. Journal of Infectious Diseases.
Kiyosawa, K.; Oofusa, H.; Saitoh, H.; Sodeyama, T.; Tanaka, E.; Furuta, S.; Itoh, S.; Ogata, H.; Kobuchi, H.; Kameko, M.; and Kanai, M. (1989). Seroepidemiology of hepatitis A, B, and D viruses and human T-lymphocyte tropic viruses in Japanese drug abusers. Journal of Medical Virology.
Klaus, M.V.; Amarante, L.; and Beam, T.R. (1989). Routine screening for syphilis is justified in patients admitted to psychiatric, alcohol, and drug rehabilitation wards of the Veterans Administration Medical Center. Archives of Dermatology.
Korzeniowski, O.; Sande, M.A.; and The National Collaborative Endocarditis Study Group. (1982). Combination antimicrobial therapy for staphylococcus aureus endocarditis in patients addicted to parenteral drugs and in nonaddicts: A prospective study. Annals of Internal Medicine.
Koutsky, L., and Wolner-Hanssen, P. (1989). Genital papillomavirus infections: Current knowledge and future prospects. Sexually Transmitted Diseases.
Krogsgaard, K.; Wantzin, P.; Mathiesen, L.R.; Sonne, J.; Ring-Larsen, H.; and The Copenhagen Hepatitis Acuta Programme. (1990). Early appearance of antibodies to hepatitis C virus in community acquired acute non-A, non-B hepatitis is associated with progression to chronic liver disease. Scandinavian Journal of Infectious Diseases.
Krueger, L.E.; Wood, R.W.; Diehr, P.H.; and Maxwell, C.L. (1990). Poverty and HIV seropositivity: The poor are more likely to be infected. AIDS.
Lange, W.R.; Ball, J.C.; Pfeiffer, M.B.; Snyder, F.R.; and Cone, E.J. (1989). The Lexington addicts, 1971-1972: Demographic characteristics, drug use patterns, and selected infectious disease experience. International Journal of the Addictions.
Lange, W.R.; Cone, E.J.; and Snyder, F.R. (1990). The association of hepatitis delta virus and hepatitis B virus in parenteral drug abusers. Archives of Internal Medicine.
Law, C.L.H.; Qassim, M.; Thompson, C.H.; Rose, B.R.; Grace, J.; Morris, B.J.; and Cossart, Y.E. (1991). Factors associated with clinical and sub-clinical anal human papillomavirus infection in homosexual men. Genitourinary Medicine.
Lee, H.H.; Weiss, S.H.; Brown, L.S.; Mildvan, D.; Shorty, V.; Saravolatz, L.; Chu, A.; Ginsburg, H.M.; Markowitz, N.; Des Jarlais, D.C.; Blattner, W.A.; and Allain, J.P. (1990). Patterns of HIV-1 and HTLV-I/II in intravenous drug abusers from the Middle Atlantic and Central regions of the USA. Journal of Infectious Diseases.
Lee, J.H.; Branan, L.; Hoff, G.L.; Datwyler, M.L.; and Bayer, W.L. (1990). Voluntary human immunodeficiency virus testing, recidivism, partner notification, and sero-prevalence in a sexually transmitted disease clinic: A need for mandatory testing. Sexually Transmitted Diseases.
Leff, D.R., and Leff, A.R. (1989). Tuberculosis control policies in major metropolitan health departments in the United States: Standards in 1988. American Review of Respiratory Disease.
Legal Action Center of the City of New York, Inc. (1991).
Lestrem, M.D.; Fainboim, H.; Mendez, N.; Boxaca, M.; Libonatti, O.; Calello, M.A.; Astarloa, L.; and Weissenbacher, M. (1989). HIV-1 infection in intravenous drug abusers with clinical manifestations of hepatitis in the city of Buenos Aires. Bulletin of the Pan American Health Organization.
Lindsay, M.K.; Peterson, H.B.; Mundy, D.C.; Slade, B.A.; Feng, T.; Willis, S.; Stine, P.; and Klein, L. (1989). Seroprevalence of human immunodeficiency virus infection in a prenatal population at high risk for HIV infection. Southern Medical Journal.
Long, R.; Scalcini, M.; Manfreda, J.; Jean-Baptiste, M.; and Hershfield, E. (1991). The impact of HIV on the usefulness of sputum smears for the diagnosis of tuberculosis. American Journal of Public Health.
Mackay, I.R. (1990). The new hepatitis virus: Hepatitis C virus. Medical Journal of Australia.
Magura, S.; Shapiro, J.L.; Grossman, J.I.; Siddiqi, Q.; Lipton, D.S.; Amann, K.R.; Koger, J.; and Gehan, K. (1990). Reactions of methadone patients to HIV antibody testing. Advances in Alcohol & Substance Abuse.
Major, C.J.; Read, S.E.; Coates, R.A.; Francis, A.; McLaughlin, B.J.; Millson, M.; Shepherd, F.; Fanning, M.; Calzavara, L.; MacFadden, D. et al. (1991). Comparison of saliva and blood for human immunodeficiency virus prevalence testing. Journal of Infectious Diseases.
Marks, G.; Richardson, J.L.; and Maldonado, N. (1991). Self-disclosure of HIV infection to sexual partners. American Journal of Public Health.
Martin, D.H.; Mroczkowski, T.F.; Dalu, Z.A.; McCarty, J.; Jones, R.B.; Hopkins, S.J.; Johnson, R.B.; and the Azithromycin for Chlamydial Infections Study Group. (1992). A controlled trial of a single dose of azithromycin for the treatment of chlamydial urethritis and cervicitis. New England Journal of Medicine.
Masur, H. (1992). Prevention and treatment of Pneumocystis pneumonia. New England Journal of Medicine.
McKegney, F.P.; O'Dowd, M.A.; Feiner, C.; Selwyn, P.; Drucker, E.; and Friedland, G.H. (1990). A prospective comparison of neuropsychologic function in HIV-seropositive and seronegative methadone-maintained patients. AIDS.
McQuillan, G.M.; Townsend, T.R.; Fields, H.A.; Carroll, M.; Leahy, M.; and Polk, B.F. (1989). Seroepidemiology of hepatitis B virus infection in the United States. American Journal of Medicine.
Medical Section of the American Lung Association,. (1992). Control of tuberculosis in the United States. American Review of Respiratory Disease.
Minkoff, H.L.; McCalla, S.; Delke, I.; Stevens, R.; Salwen, M.; and Feldman, J. (1990). The relationship of cocaine use to syphilis and human immunodeficiency virus infections among inner city parturient women. American Journal of Obstetrics and Gynecology.
Morris, B.J.; Rose, B.R.; Flanagan, J.L.; McKinnon, K.J.; Loo, C.Y.; Thompson, C.H.; Flampoulidou, M.; Ford, R.M.; Hunter, J.C.; Nightingale, B.N.; and Cossart, Y.E. (1990). Automated polymerase chain reaction for papillomavirus screening of cervicovaginal lavages: Comparison with dot-blot hybridization in a sexually transmitted diseases clinic population. Journal of Medical Virology.
Moss, A.R., and Vranizan, K. (1992). Charting the epidemic: The case study of HIV screening of injecting drug users in San Francisco, 1985-1990. British Journal of Addiction.
Murphy, T.F. (1991 (commentary)). Women and drug users: The changing faces of HIV clinical drug trials. Quality Review Bulletin.
Musher, D.M. (1991). Syphilis, neurosyphilis, penicillin, and AIDS. Journal of Infectious Diseases.
National Institute of Allergy and Infectious Diseases. (1993). HIV therapy guidelines issued.
Novick, D.M.; Farci, P.; Croxson, T.S.; Taylor, M.B.; Schneebaum, C.W.; Lai, M.E.; Bach, N.; Senie, R.T.; Gelb, A.M.; and Kreek, M.J. (1988). Hepatitis D virus and human immunodeficiency virus antibodies in parenteral drug abusers who are hepatitis B surface antigen positive. Journal of Infectious Diseases.
Occupational Safety and Health Administration. (1991).
Omar, R.; Choudhury, M.; Fischer, J.; and Ezpeleta, C. (1991). A "Pap" test for men? Male urethral smears as screening tool for detecting subclinical human papillomavirus infection. Urology.
Pantaleo, G.; Graziosi, C.; Demarest, J.F.; Butini, L.; Montroni, M.; Fox, C.H.; Orenstein, J.M.; Kotler, D.P.; and Fauci, A.S. (1993). HIV infection is active and progressive in lymphoid tissue during the clinically latent stage of the disease. Nature.
Perry, S.; Jacobsberg, L.B.; Fishman, B.; Frances, A.; Bobo, J.; and Jacobsberg, B.K. (1990). Psychiatric diagnosis before serological testing for the human immunodeficiency virus. American Journal of Psychiatry.
Pond, S.M.; Kreek, M.J.; Raghunath, J.; and Benowitz, N.L. (1985). Altered methadone pharmacokinetics in methadone-maintained pregnant women. Journal of Pharmacology and Experimental Therapeutics.
Quinn, T.C.; Cannon, R.O.; Glasser, D.; Groseclose, S.L.; Brathwaite, W.S.; Fauci, A.S.; and Hook, E.W. (1990). The association of syphilis with risk of human immunodeficiency virus infection in patients attending sexually transmitted disease clinics. Archives of Internal Medicine.
Reid, R., and Lorincz, A.T. (1991). Should family physicians test for human papillomavirus infection? An affirmative view. Journal of Family Practice.
Report of the Committee on Infectious Diseases. (1991).
Rhame, F.S., and Maki, D.G. (1989). The case for wider use of testing for HIV infection. New England Journal of Medicine.
Ricci, J.M.; Fojaco, R.M.; and O'Sullivan, M.J. (1989). Congenital syphilis: The University of Miami/Jackson Memorial Medical Center experience, 1986-1988. Obstetrics and Gynecology.
Riley, R.L., and Nardell, E.A. (1989). Clearing the air: The theory and application of ultraviolet air disinfection. American Review of Respiratory Disease.
Robert-Guroff, M.; Weiss, S.H.; Giron, J.A.; Jennings, A.M.; Ginzburg, H.M.; Margolis, I.B.; Blattner, W.A.; and Gallo, R.C. (1986). Prevalence of antibodies to HTLV-I, -II, and -III in intravenous drug abusers from an AIDS endemic region. Journal of the American Medical Association.
Robinson, W.S. (1990). Hepatitis B virus and hepatitis delta virus. In: Mandell, G.L.; Douglas, R.G.; and Bennett, J.E., eds. Principles and Practice of Infectious Diseases.
Rosenfeld, W.D.; Vermund, S.H.; Wentz, S.J.; and Burk, R.D. (1989). High prevalence rate of human papillomavirus infection and association with abnormal papanicolaou smears in sexually active adolescents. American Journal of Diseases of Children.
Rothenberg, R.B. (1991 (editorial)). Those other STDs. American Journal of Public Health.
Rugg, D.C.; MacGowan, R.J.; Stark, K.A.; and Swanson, N.M. (1991). Evaluating the CDC program for HIV counseling and testing. Public Health Reports.
Sanchez-Quijano, A.; Rey, C.; Aguado, I.; Pineda, J.A.; Perez-Romero, M.; Torres, Y.; Leal, M.; and Lissen, E. (1990). Hepatitis C virus infection in sexually promiscuous groups. European Journal of Clinical Microbiology and Infectious Diseases.
Schade, C.P., and Komorwska, D. (1988). Continuing outbreak of hepatitis A linked with intravenous drug abuse in Multnomah County. Public Health Reports.
Scheidegger, C., and Zimmerli, W. (1989). Infectious complications in drug addicts: Seven-year review of 269 hospitalized narcotics abusers in Switzerland. Reviews of Infectious Diseases.
Schuster, C.R. (1988). Intravenous drug use and AIDS prevention. Public Health Reports.
Selik, R.M.; Buehler, J.W.; Karon, J.M.; Chamberland, M.E.; and Berkelman, R.L. (1990). Impact of the 1987 revision of the case definition of acquired immune deficiency syndrome in the United States. Journal of the Acquired Immune Deficiency Syndromes.
Selwyn, P.A. (1991 (editorial)). Injection drug use, mortality, and the AIDS epidemic. American Journal of Public Health.
Selwyn, P.A.; Hartel, D.; Lewis, V.A.; Schoenbaum, E.E.; Vermund, S.H.; Klein, R.S.; Walker, A.T.; and Friedland, G.H. (1989). A prospective study of the risk of tuberculosis among intravenous drug users with human immunodeficiency virus infection. New England Journal of Medicine.
Selwyn, P.A.; Sckell, B.M.; Alcabes, P.; Friedland, G.H.; Klein, R.S.; and Schoenbaum, E.E. (1992). High risk of active tuberculosis in HIV-infected drug users with cutaneous anergy. Journal of the American Medical Association.
Siegel, J.E.; Weinstein, M.C.; and Fineberg, H.V. (1991). Bleach programs for preventing AIDS among IV drug users: Modeling the impact of HIV prevalence. American Journal of Public Health.
Simmonds, P.; Zhang, L.Q.; Watson, H.G.; Rebus, S.; Ferguson, E.D.; Balfe, P.; Leadbetter, G.H.; Yap, P.L.; Peutherer, J.F.; and Ludlam, C.A. (1990). Hepatitis C quantification and sequencing in blood products, haemophiliacs, and drug users. Lancet.
Small, P.M., and Chambers, H.F. (1990). Vancomycin for staphylococcus aureus endocarditis in intravenous drug users. Antimicrobial Agents and Chemotherapy.
Solomon, L; Frank, R.; Vlahov, D.; and Astemborski, J. (1991). Utilization of health services in a cohort of intravenous drug users with known HIV-1 serostatus. American Journal of Public Health.
Sonnex, C.; Petherick, A.; Hart, G.J.; and Adler, M.W. (1989). An appraisal of HIV antibody test counselling of injecting drug users. AIDS Care.
Spencer, S.S., and Morton, A.R. (1989). Tuberculosis surveillance in a State prison system. American Journal of Public Health.
Spitzer, M.; Brandsma, J.L.; Steinberg, B.; Chernys, A.E.; and Krumholz, B.A. (1990). Detection of conditions related to human papillomavirus: Comparison of cytology, colposcopy, histology and hybridization. Journal of Reproductive Medicine.
Stanford, J.L. (1991). Improving on BCG. APMIS.
Stiffman, A.R., and Earls, F. (1990). Behavioral risks for human immunodeficiency virus infection in adolescent medical patients. Pediatrics.
Struve, J.; Giesecke, J.; Lindh, G.; and Weiland, O. (1990). Heterosexual contact as a major route for transmission of acute hepatitis B among adults. Journal of Infection.
Suarez, M.; Briones, H.; and Saaevdra, T. (1991). Buttock herpes: High risk in pregnancy. Journal of Reproductive Medicine.
Syrjanen, K. (1989). Epidemiology of human papillomavirus (HPV) infections and their associations with genital squamous cell cancer. APMIS.
Tor, J.; Llibre, J.M.; Carbonell, M.; Muga, R.; Ribera, A.; Soriano, V.; Clotet, B.; Sabria, M.; and Foz, M. (1990). Sexual transmission of hepatitis C virus and its relation with hepatitis B virus and HIV. British Medical Journal.
Torres, R.A.; Mani, S.; Altholz, J.; and Brickner, P.W. (1990). Human immunodeficiency virus infection among homeless men in a New York City shelter: Association with Mycobacterium tuberculosis infection. Archives of Internal Medicine.
Tramont, E.C. (1990). Treponema pallidum. In: Mandell, G.L.; Douglas, R.G.; and Bennett, J.E., eds.
Tucker, R.M.; Gaffey, M.J.; Fisch, M.J.; Kaiser, D.L.; Guerrant, R.L.; and Normansell, D.E. (1987). Seroepidemiology of hepatitis D (delta agent) and hepatitis B among Virginia State prisoners. Clinical Therapeutics.
U.S. Preventive Services Task Force. (1989). Screening for HIV.
U.S. Preventive Services Task Force. (1990). Screening for sexually transmitted diseases. American Family Physician.
Van Den Brule, A.J.C.; Meijer, C.J.L.M.; Bakels, V.; Kenemans, P.; and Walboomers, J.M.M. (1990). Rapid detection of human papillomavirus in cervical scrapes by combined general primer-mediated and type-specific polymerase chain reaction. Journal of Clinical Microbiology.
Vlahov, D.; Munoz, A.; Anthony, J.C.; Cohn, S.; Celentano, D.D.; and Nelson, K.E. (1990). Association of drug injection patterns with antibody to human immunodeficiency virus type 1 among intravenous drug users in Baltimore, Maryland. American Journal of Epidemiology.
Weiss, S.H. (1989 (editorial)). Links between cocaine and retroviral infection. Journal of the American Medical Association.
[Weiss, S.H.]. (1989 (correspondence)). Unusual modes of HIV transmission. New England Journal of Medicine.
Wolff, K.; Shanab, M.A.; Sanderson, M.J.; and Hay, A.W. (1990). Screening for drugs of abuse: Effect of heat-treating urine for safe handling of samples. Clinical Chemistry.