# Appendix G - HIV/AIDS Prevention Bulletin

The HIV/AIDS Prevention Bulletin is unavailable in electronic form as part of TIP 6: Screening for Infectious Diseases Among Substance Abusers.

A copy of the entire TIP containing the HIV/AIDS Prevention Bulletin can be ordered from the National Clearinghouse of Drug and Alcohol Information (NCADI). The order number for TIP 6: Screening for Infectious Diseases Among Substance Abusers is BKD131. It is free and can be ordered from NCADI's electronic catalog at http://www.health.org/pubs/catalog/ordering.htm or by calling 1-800-729-6686.