# Appendix E - Program Models and Sample Budgets

This section presents three program models and related sample budgets to assist State agency and local alcohol and other drug treatment staff to screen for infectious diseases. The program models reflect the recommendations of alcohol, drug abuse, and mental health (ADM) experts for specific services and staffing. The sample budgets present costing data and assumptions developed by ADM financial experts.

The three program models are

- Model A, which offers counseling and testing for HIV/AIDS (tables 1 and 1a )
- Model B, which offers screening for infectious diseases not including HIV/AIDS (tables 2 and 2a)
- Model C, which offers a combination of the above two models--HIV/AIDS counseling and testing combined with other infectious disease screening (tables 3 and 3a )

Table 1. Model A - Tasks, staffing, and time for HIV-antibody counseling and testing

Table 1. Model A - Tasks, staffing, and time for HIV-antibody counseling and testing
Task | Staff^1^ | Time per task(per client) | Total hours^2^ 150 Slots
Evaluation | Intake worker Counselor Intern | 2 hours | 400
Physical and followup | Physician Physician's assistant Nurse practitioner | 45 minutes | 150
Assist physician | Nurse | 45 minutes | 150
Lab work--routine | Phlebotomist or refer to outside laboratory | 20 minutes | 67
Unable to obtain sample | Refer to outside physician, outside clinic/hospital for femoral stick
Counseling and testing for HIV/AIDS | Counselor Pre-test counseling Post-test counseling | 30 minutes 45 minutes | 100 150
Treatment planning | Counselor | 30 minutes | 100
Counseling, education, treatment planning, and case management | Case manager Nurse Health educator | 47 hours(5 FTEs per 150 patients) | 9,400
^1^ All staff trained and experienced in drug treatment and HIV/AIDS. ^2^ Consists of a time--allocation formula of 75 percent for direct services and 25 percent for indirect services.

Table 1a. Model A - HIV-antibody counseling and testing program sample budget for 150 treatment slots

Table 1a. Model A - HIV-antibody counseling and testing program sample budget for 150 treatment slots
Personnel Costs
Position | Hours required | Full-time equivalents needed | Compensation | Total cost
Intake/Counselor | 750 | 0.40 | $25,000 per year | $ 10,000
Case manager | 9,400 | 5.00 | $30,000 per year | 150,000
Physician | 150 | 0.08 | $100 per hour | 15,000
Nurse/Nurse practitioner | 150 | 0.08 | $20 per hour | 3,000
Total Wages | | | | $178,000
Fringe Benefits @ 30% of wages | | | | 53,400
Total Personnel Costs | | | | $231,400
Other Costs | | | | Cost
Laboratory (150 patients @ $101) | | | | $15,150
Phlebotomy (67 hours for a phlebotomist @ $20/hr.) | | | | 1,340
Clinical Supplies (150 patients @ $20) | | | | 3,000
Publications | | | | 1,000
Training and Conferences (8 staff @ $500) | | | | 3,000
Transportation (150 patients @ $20) | | | | 3,000
Administrative Support (20% of wages + fringes) | | | | 46,280
Total Other Cost | | | | $73,770
Total Personnel and Other Costs | | | | $305,170

Table 2. Model B - Tasks, staffing, and time for screening for infectious diseases (not including HIV)

Table 2. Model B - Tasks, staffing, and time for screening for infectious diseases (not including HIV)
Task | Staff^1^ | Time per task (per client) | Total hours^2 ^150 Slots
Evaluation | Intake worker Counselor Intern | 2 hours | 400
Physical and followup | Physician Physician's assistant Nurse practitioner | 30 to 45 minutes per client, 4 to 6 clients per 8 hours | 150
Assist physician | Nurse | 45 minutes | 150
Lab work--routine | Phlebotomist or refer to outside laboratory | 20 minutes | 67
Unable to obtain sample due to lack of veins | Refer to outside physician, outside clinic/hospital for femoral stick
Counseling, education, treatment planning, and case management | Case manager Nurse Health educator | 19 hours (2 FTEs per 150 patients) | 3,760
^1^ All staff trained and experienced in drug treatment and HIV/AIDS. ^2^ Consists of a time-allocation formula of 75 percent for direct services and 25 percent for indirect services.

Table 2a. Model B - Infectious diseases screening program sample budget for 150 treatment slots

Table 2a. Model B - Infectious diseases screening program sample budget for 150 treatment slots
Personnel Costs
Position | Hours required | Full-time equivalents needed | Compensation | Total cost
Intake/Evaluation | 400 | 0.25 | $25,000 per year | $ 6,250
Case manager | 3,760 | 2.00 | $30,000 per year | 60,000
Physician | 150 | 0.08 | $100 per hour | 15,000
Nurse/Nurse practitioner | 150 | 0.08 | $20 per hour | 3,000
Total Wages | | | | $84,250
Fringe Benefits @ 30% of wages | | | | 25,275
Total Personnel Costs | | | | $109,525
Other Costs | | | | Cost
Laboratory (150 patients @ $1,355) | | | | $203,250
Phlebotomy (67 hours for a phlebotomist @ $20/hr.) | | | | 1,340
Clinical Supplies (150 patients @ $20) | | | | 3,000
Publications | | | | 500
Training and Conferences (8 staff @ $500) | | | | 1,250
Transportation (150 patients @ $20) | | | | 3,000
Administrative Support (20% of wages + fringes) | | | | 21,905
Total Other Cost | | | | $234,245
Total Personnel and Other Costs | | | | $343,770

Table 3. Model C - Tasks, staffing, and time for HIV-antibody counseling and testing and screening for other infectious diseases

Table 3. Model C - Tasks, staffing, and time for HIV-antibody counseling and testing and screening for other infectious diseases
Task | Staff^1^ | Time per task (per client) | Total hours^2 ^150 Slots
Evaluation | Intake worker Counselor Intern | 150 minutes | 500
Physical and followup | Physician Physician's assistant Nurse practitioner | 60 minutes | 200
Assist physician | Nurse | 60 minutes | 200
Lab work--routine | Phlebotomist or refer to outside laboratory | 30 minutes | 100
Unable to obtain sample due to lack of veins | Refer to outside physician, outside clinic/hospital for femoral stick
Counseling, education, treatment planning, and case management | Case manager Nurse Health educator | 66 hours (2 FTEs per 150 patients) | 13,160
^1^ All staff trained and experienced in drug treatment and HIV/AIDS. ^2^ Consists of a time-allocation formula of 75 percent for direct services and 25 percent for indirect services.

Table 3a. Model C - Tasks, staffing, and time for HIV-antibody counseling and testing and screening for other infectious diseases

Table 3a. Model C - Tasks, staffing, and time for HIV-antibody counseling and testing and screening for other infectious diseases
Personnel Costs
Position | Hours required | Full-time equivalents needed | Compensation | Total cost
Intake/Counselor | 850 | 0.50 | $25,000 per year | $ 12,500
Case manager | 13,160 | 7.00 | $30,000 per year | 210,000
Physician | 200 | 0.11 | $100 per hour | 20,000
Nurse/Nurse practitioner | 200 | 0.11 | $20 per hour | 4,000
Total Wages | | | | $246,500
Fringe Benefits @ 30% of wages | | | | 73,950
Total Personnel Costs | | | | $320,450
Other Costs | | | | Cost
Laboratory (150 patients @ $1,456) | | | | $218,400
Phlebotomy (100 hours for a phlebotomist @ $20/hr.) | | | | 2,000
Clinical Supplies (150 patients @ $20) | | | | 3,000
Publications | | | | 1,000
Training and Conferences (10 staff @ $500) | | | | 5,000
Transportation (150 patients @ $20) | | | | 3,000
Administrative Support (20% of wages + fringes) | | | | 64,090
Total Other Cost | | | | $296,490
Total Personnel and Other Costs | | | | $616,940

These program models have been designed with the understanding that not all States or localities are able to begin new programs or to expand their already-existing screening services. It is further recognized that some States and localities may not offer infectious disease screening and do not expect to receive funds to do so in the future. The program models are intended to be used as guides or standards by those who can develop new services or incorporate some of the guidelines into existing programs.

The accompanying tables present the major tasks, necessary staff, and time estimates for implementing each of the program models. A list of Medicaid reimbursement rates for various medical procedures is included as a guide (table 4). These rates represent the average reimbursement rate paid to States for specific procedures. A program's actual reimbursement rate for individual procedures may vary.

Table 4. Medicaid reimbursement rates for medical procedures

Table 4. Medicaid reimbursement rates for medical procedures
Physicians' Current Procedural Terminology code | Name of procedure by category | Medicaid payment
Radiology
71010 | Chest x-ray | $ 9.76
Chemistry
80004 | Electrolytes | 8.43
80006 | Chem 6 | 8.98
80009 | Liver profile | 11.09
80012 | Chem 12 | 10.80
80018 | Chem 18 (17--18 tests) | 14.33
80019 | Chem 20 (a generic for more than 19 tests) | 15.04
84450 | AST (SGOT) | 5.91
84460 | ALT (SGPT) | 5.83
80070 | Thyroid panel | 16.19
82150 | Amylase | 8.57
83690 | Lipase | 8.22
82947 | Glucose tests | 5.23
82952 | Glucose challenge | 7.01
83705 | Lipids, fractionated: cholesterol, triglycerides, and phospholipids | 15.28
86244 | Alpha-fetoprotein | 18.09
Hematology
83020 | Hemoglobin, electrophresis | 12.54
83053 | Sickle cell | 6.93
85024 | CBC--complete blood count | 10.98
86082 | ABO type and Rh factor | 6.72
88180 | Total CD4 count; CD4:CD8 (T4:T8) ratio | 45.76
Toxicology
82055 | Blood alcohol | 15.56
82065 | Alcohol (Blood or urine) | 13.33
82660 | Urine drug screen panel | 14.49
83645 | Lead screening, blood | 8.61
82840 | Methadone | 8.95
Urinalysis
81000 | Routine urinalysis, including microscopic examination | $ 4.64
Pathology
47120 | Liver biopsy | 484.62
88150 | Papanicolaou smear | 7.18
88312 | Special stains for tissue scrapping for herpes virus or tissue biopsy | 13.73
Microbiology
87040 | Bacterial blood culture | 14.12
87087 | Urine culture | 6.49
87116 | Culture, tubercle or other acid-fast bacilli (e.g., TB, AFB, mycobacteria); any source, isolation only | 8.89
87118 | Culture, mycobacteria, definitive identification of each organism | 14.27
87205 | Smear, with interpretation; routine stain for bacteria, fungi, or cell types (e.g., cervical smear--gonorrhea) | 5.43
Gonorrhea
87070 | Neisseria gonorrhea culture | 11.93
87163 | Culture of discharge from mucosal surfaces in Thayer-Martin (chocolate agar supplemented with antibiotics) | 14.21
Serology
82784 | Immunoglobulin G, A, M, D | 14.50
84231 | Solid-phase radioimmunoassay (RIA) | 18.12
86016 | Antibody screen | 8.89
86255 | Fluorescent antibody (e.g., chlamydia, herpes screening) | 12.81
86317 | Immunoassay for infectious agent antigen or antibody (e.g., chlamydia) | 15.73
86320 | Serum gammaglobulin levels | 27.09
86403 | Particle agglutination rapid test (e.g., rubella antibody; cryptoccocal antigen) | 13.77
88346 | Immunofluorescent stain (e.g., chlamydia DFA or herpes DFA) | $33.47
HIV
86312 | HIV-EIA (enzyme immune assay) | 13.06
86314 | Confirmatory test for HIV (Western blot) | 27.93
Syphilis
86592 | RPR--syphilis (qualitative) | 4.70
86593 | VDRL--venereal disease reference laboratory (quantitative) | 5.84
86650 | FTA-ABS | 14.44
Tuberculosis
86580 | Tuberculosis intradermal skin test (Mantoux text) | 6.49
Hepatitis
80059 | Hepatitis profile | 42.74
Hepatitis B
86287 | Hepatitis B surface antigen screen | 13.89
86289 | Anti-hepatitis B core antibody | 16.48
86291 | HBsAb--hepatitis B surface antibody | 14.83
Hepatitis A
86299 | Hepatitis A (IgM Anti-HAV) | 14.92
Hepatitis B vaccine
90731 | Recombivax HB (MSD) vaccine | 34.47
90742 | Energix-B (SK Biologicals) | 37.50
SOURCE: Special analysis for CSAT done by the Division of Medicaid Statistics, Office of Program Systems, Bureau of Data Management and Strategy, Health Care Financing Administration. Data are from the period July<196>September 1991. The data were obtained from the individual claims data supplied by State Medicaid agencies to the Medicaid Statistical Information System at the Health Care Financing Administration. The participating States were Alaska, Alabama, California, Delaware, Georgia, Indiana, Iowa, Kansas, Kentucky, Maine, Missouri, Montana, New Jersey, North Dakota, New Hampshire, Utah, Vermont, Washington, Wisconsin, and Wyoming.

The sample budgets that follow the tables are based on the program models and lay out the requirements and formulas for estimating program costs. The cost assumptions should be adjusted to conditions that prevail in different geographic areas. For example, to estimate labor costs in a specific location, the prevailing salary/wage rates can be substituted for the rates used here.

## Overview of the Program Models

The three program models presented in this section add a variety of services to an existing drug treatment program. The models assume a case management approach and 150 treatment slots per program. The tables present the following information for each program model:

- Functional tasks
- Staff needed to perform each task
- Time needed to complete each task
- Total number of direct and indirect service hours needed for 150 patient slots

The staffing levels presented in the tables allocate time for each task on a formula of 75 percent for direct service and 25 percent for indirect service. Indirect service time is computed as part of the total time needed to complete all tasks appropriately. For example, for each hour of staff work, 45 minutes is devoted to direct client service and 15 minutes is allotted for tasks such as charting and telephone calls. The staffing levels presented in the tables do not take into account tasks performed by administrative, managerial, and support personnel, such as a receptionist who answers the telephone and schedules appointments.

It is expected that there will be patient attrition for a variety of reasons. Staffing, patient scheduling, and screening will vary throughout the year due to the nature of the population and because of the need to screen or test for diseases more than once a year.

## Overview of the Sample Budgets

The costs associated with the operation of each program model are presented in the sample budgets. Patients will be entering and leaving the program at different points in the treatment continuum; however, the sample budgets are based on a static patient population of 150 patient slots.

The sample budgets are based on these assumptions:

- The costs reflect fully operational programs at 150 patient slots.
- The tables identify a choice of professionals who could perform each task. For example, physicians and registered nurses are selected to provide the medical services. An intake worker and counselor are allotted to provide evaluation, counseling, and treatment planning services. In addition, salary ranges for social workers are used for the case manager positions.
- The wage rates are based on a limited survey. Actual salaries should be adjusted to prevailing wage rates for the geographic area.
- One full-time equivalent (FTE) position provides for 1,880 hours of service plus 80 hours of vacation and 40 hours of sick leave.
- The physician and nursing positions are paid on an hourly basis.
- The intake counselor and case manager positions are salaried.
- Laboratory costs per treatment slot are as follows:
  - Infectious disease screenings/tests - $1,355
  - HIV-antibody testing - $101
  - Combined HIV-antibody testing and infectious disease screenings/tests - $1,456
- Laboratory charges are based on a limited national survey and on single-unit prices. Actual costs will vary by geographic area, particularly if volume discounts are available.
- Phlebotomy services are obtained from an outside laboratory rather than performed by a staff member. Costs are calculated at $20 per hour.
- Clinical supplies are computed at $20 per patient slot per year.
- A transportation allowance of $20 per patient slot is included in the budgets to cover the cost of bus tokens or cab vouchers.
- Training and conference allowance costs are:
  - HIV counseling and testing program - $500 per staff member
  - Infectious diseases screening program - $250 per staff member
- The fringe benefit rate is calculated at 30 percent.
- An administrative overhead charge of 20 percent of total wages and fringe benefits is included in the budgets to provide for the costs of administrative supervision and support.
- The budgets do not include indirect costs necessary for the operation of a facility. Examples of indirect costs that should be considered part of an operating budget include:
  - space rental
  - utilities
  - telephone
  - cleaning
  - insurance
  - equipment purchase/rental and maintenance/ repairs
  - office supplies
  - depreciation
  - security services
- The budgets do not consider reimbursement issues. Before deciding to implement these guidelines, it may be advantageous to study Federal, State, local, and third-party reimbursement programs. Reimbursements from these sources may pay for part or all of the services offered by the program models.

## Summary

The program models and sample budgets in this section provide examples of how to design and implement three different approaches to screening for infectious diseases in a drug treatment program. This information permits comparison between the costs of delivering separate or combined HIV/AIDS counseling and testing and infectious diseases screening programs. The economies of scale clearly indicate a cost advantage to a combined program. The HIV/< AIDS counseling and testing operation is a labor-driven program, while the infectious diseases screening program mainly involves costs for laboratory procedures. The combining of both HIV/AIDS counseling and testing and infectious diseases screening would allow for the greatest amount of programmatic and fiscal flexibility.

The number of patients in drug treatment programs with HIV/AIDS and infectious diseases continues to grow. At the present time, there is no reason to believe that this population will be decreasing in size. Given the strong correlation between HIV, infectious diseases, and chemical dependency, there is a need for drug treatment programs to consider enhancing their efforts by including counseling, testing, and screening services. The information provided in the guidelines, along with suggestions in this section for service design and implementation, staffing, and costing, are intended to guide States and local treatment programs in their efforts to provide services to this population.