# Appendix D - Resource List

Issues for Treatment Program Administration" this volume, identifies several published guidelines and advisories for infectious disease prevention and control. In addition to the listed guidelines, Federal and State agencies offer a wide variety of related resources; some of them are listed below.

The HIV and Substance Abuse Training Curriculum: A Catalog of Training Material Available from the National Institute on Drug Abuse (NIDA). Federal program contact: Susan L. David, Chief, Community and Professional Education Branch, National Institute on Drug Abuse, 5600 Fishers Lane, Room 10A-39, Rockville, MD 20857. (301) 443-1124, FAX (301) 443-7397.

Directory of Projects: Faculty Development Program in Alcohol and Other Drug Abuse. Published by the National Institute on Alcohol Abuse and Alcoholism (NIAAA), the National Institute on Drug Abuse (NIDA), and the Center for Substance Abuse Prevention (CSAP). Federal program contacts: Lucille C. Perez, M.D., Associate Director for Medical and Clinical Affairs, Center for Substance Abuse Prevention, 5600 Fishers Lane, Rockwall II, Rockville, MD 20857. (301) 443-9351; Frances Cotter, M.P.H., Public Health Adviser, NIAAA, 5600 Fishers Lane, Room 14C-20, Rockville, MD, 20857. (301) 443-1207; and Dorynne Czechowicz, M.D., Associate Director for Medical and Professional Affairs, NIAAA, 5600 Fishers Lane, Room 10A-12, Rockville, MD, 20857. (301) 443-4877.

National Clearinghouse for Alcohol and Drug Information (NCADI) Publications Catalog, Post Office Box 2345, Rockville, MD 20847-2345. 1-800-729-6686 or (301) 468-2600.

The Office for Substance Abuse Prevention (OSAP) National Training System. Federal program contact: Steven Seitz, Project Officer, Training and Evaluation Branch, Division of Community Prevention and Training, OSAP, 5600 Fishers Lane, Rockwall II, Rockville, MD 20857. (301) 443-5276.

The OSAP Prevention Training Information System. Federal program contact: Edward Briggs, (301) 588-5484.

The Federal alcohol and drug clearinghouses listed below can all be reached through one telephone number: 1-800-788-2800. Callers can reach the individual clearinghouses directly at the numbers listed below.

National Clearinghouse for Alcohol and Drug Information (NCADI). 1-800-729-6686. Operated by the Center for Substance Abuse Prevention of the Department of Health and Human Services, NCADI distributes a wide range of printed and audiovisual materials, including posters, fact sheets, curriculum descriptions, and articles. There is a large full-service library. NCADI coordinates the Regional Alcohol and Drug Awareness Network (RADAR), which facilitates access to State and local sources of information about alcohol and other drugs.

National AIDS Clearinghouse. 1-800-458-5231; TTY: 1-800-243-7012. Operated by the Centers for Disease Control and Prevention. Central source of information on AIDS and HIV, including information on the relationship between drug abuse and AIDS. English- and Spanish-speaking reference specialists assist in providing access to more than 6,000 educational materials and computerized databases of materials, service organizations, funding sources, and conferences. Information on AIDS clinical trials is available at 1-800-874-2572.

Drug Information and Strategy Clearinghouse. 1-800-245-2691 and (301) 251-5154. Operated by the Office for Drug-Free Neighborhoods, Department of Housing and Urban Development. Provides information on preventing drug abuse and drug trafficking in public and assisted housing.

Drug Abuse Information and Treatment Referral Line. 1-800-662-4357; Spanish: 1-800-662-9832. Operated by the National Institute on Drug Abuse and the Center for Substance Abuse Treatment. Provides information about drug use, treatment, support groups, and services. Information counselors can discuss problems and provide referrals to State and local drug treatment facilities and programs.

Drug-Free Workplace Helpline. 1-800-843-4971. Operated by the Center for Substance Abuse Prevention. Provides telephone consultation, resource referrals, networking services, and publications to business, industry, and unions to assist in planning, developing, and implementing comprehensive drug-free workplace programs.

There are other sources of information that may be of interest:

- Resource Center on Substance Abuse Prevention and Disability. 1-202-783-2900; TDD: (202) 737-0725. Funded by the Center for Substance Abuse Prevention. Answers questions about alcohol and other drug abuse prevention and treatment issues for persons with disabilities; services include customized database searches and fact sheets.
- Anti-Drug Information Center. 1-800-225-3784; by modem: 1-800-225-3804. Operated by the Department of Transportation. Provides access to all regulatory information related to the Department's anti-drug programs.