# Appendix C - TIP Field Reviewers

- Charles E. Bell, M.D.
- Bureau Chief
- Bureau of HIV and STD Control
- Texas Department of Health
- Austin, Texas

- Stuart M. Berman, M.D.
- Special Assistant for Perinatal and Adolescent Studies
- Clinical Research Branch
- Division of STD/HIV Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Casey S. Blass
- Director
- STD Control Division
- Texas Department of Health
- Austin, Texas

- Bernard Branson, M.D.
- Medical Epidemiologist, Viral Studies Section
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- John A. Bybee
- Tuberculosis
- Bureau of Disease Control and Epidemiology
- Texas Department of Health
- Austin, Texas

- Margaret Cone
- Division of Mental Health, Mental Retardation and Substance Abuse Services/Prevention Resource Center
- Georgia Department of Human Resources
- Atlanta, Georgia

- Wendy S. Craytor
- Coordinator, AIDS and STD Programs
- Section of Epidemiology
- Department of Health and Social Services
- State of Alaska
- Anchorage, Alaska

- Robert D. Crider, Jr.
- Immunization
- Bureau of Disease Control and Epidemiology
- Texas Department of Health
- Austin, Texas

- Alfred DeMaria, Jr., M.D.
- Assistant Commissioner for Communicable Disease Control
- State Epidemiologist
- Massachusetts Department of Public Health
- Jamaica Plain, Massachusetts

- Beth A. Dillon, M.S.W.
- Unit Chief, Program Development/Technical Support Section
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- James M. Donagher, M.A.
- HIV Coordinator
- Connecticut Alcohol and Drug Abuse Commission (CADAC)
- Hartford, Connecticut

- Samuel W. Dooley, Jr., M.D.
- Medical Epidemiologist
- Division of Tuberculosis Elimination
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Richard K. Fuller, M.D.
- Director, Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, Maryland

- Kristine M. Gebbie, R.N., M.N., FAAN
- National AIDS Policy Coordinator

- Washington, D.C.
- Dorothy C. Gunter, M.P.H.
- Public Health Adviser
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Christopher H. Hayden
- Chief, Program Support Section
- Division of Tuberculosis Elimination
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Joseph P. Iser, M.D.
- Chief Medical Officer
- Office of the Associate Administrator for AIDS
- Health Resources and Services Administration
- Rockville, Maryland

- Elaine M. Johnson, Ph.D.
- Director
- Office for Substance Abuse Prevention
- Alcohol, Drug Abuse and Mental Health Administration
- Rockville, Maryland

- Robert Johnson, M.D., M.P.H.
- Chief, Bacterial Studies Section
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- T. Stephen Jones, M.D.
- Assistant Director for Substance Abuse and HIV Prevention
- Office of the Director, HIV/AIDS
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Francis A. McCorry, Ph.D.
- Director, HIV Services
- New York State Division of Substance Abuse Services
- New York, New York

- Bess Miller, M.D., M.Sc.
- Deputy Chief, Program Services Branch
- Division of Tuberculosis Elimination
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Howard L. Minkoff, M.D.
- Professor, Obstetrics
- State University of New York
- Health Science Center at Brooklyn
- Brooklyn, New York

- Linda S. Moore, M.S., R.N.
- Nurse Consultant
- Bureau of HIV and STD Control
- Texas Department of Health
- Austin, Texas

- Gloria J. Mouzon, M.D., F.A.A.F.P.
- Interventions/Crossroads Outpatient Services
- Chicago, Illinois

- Sondra A. Nelson
- Director of AIDS Policy and Perinatal Services
- National Association of State Alcohol and Drug Abuse Directors (NASADAD)
- Washington, D.C.

- Lloyd F. Novick, M.D.
- Director
- Center for Community Health
- Department of Health
- State of New York
- Albany, New York

- Catherine H. O'Neill, J.D.
- HIV/AIDS Project Director
- Executive Vice President
- Legal Action Center
- New York, New York

- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates, Inc.
- San Antonio, Texas

- Dennis M. Perrotta, Ph.D.
- Endocarditis
- Bureau of Disease Control and Epidemiology
- Texas Department of Health
- Austin, Texas

- Louis B. Polish, M.D.
- Medical Epidemiologist
- Hepatitis Branch
- Division of Viral and Rickettsial Diseases
- National Center for Infectious Diseases
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Norbert P. Rapoza, Ph.D.
- Director, Department of Immunology and Infectious Diseases
- American Medical Association
- Chicago, Illinois

- Beverly Ray, R.N.
- Septicemia/Bacteremia
- Bureau of Disease Control and Epidemiology
- Texas Department of Health
- Austin, Texas

- Charles P. Schade, M.D., M.P.H.
- Associate Executive Director
- Professional Affairs
- American Public Health Association
- Washington, D.C.

- William O. Schalla, M.S.
- Chief, Model Performance Evaluation Program
- Division of Laboratory Systems
- Public Health Practice Program Office
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- George Schmid, M.D.
- Chief, Clinical Research Branch
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Lynne M. Sehulster, Ph.D.
- ASCP, Hepatitis A, B, C, D,
- Bureau of Disease Control and Epidemiology
- Texas Department of Health
- Austin, Texas

- Peter A. Selwyn, M.D., M.P.H.
- Associate Director, AIDS Program
- Associate Professor of Medicine and Epidemiology and Public Health
- School of Medicine
- Yale University
- New Haven, Connecticut

- Diane M. Simpson, Ph.D., M.D.
- Associate Commissioner
- Disease Prevention
- Bureau of Disease Control and Epidemiology
- Texas Department of Health
- Austin, Texas

- Jerry Swank, M.B.A., NCACII, CAAP
- AIDS Program Coordinator
- Department of Health and Rehabilitative Services
- Alcohol and Drug Abuse Program
- State of Florida
- Tallahassee, Florida

- Ronald O. Valdiserri, M.D., M.P.H.
- Deputy Director, Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Patsy R. Verret, R.N. CD, CCDN
- Registered Nurse Program Coordinator
- Office of Human Services
- Division of Alcohol and Drug Abuse
- Lafayette Alcohol and Drug Abuse Clinic
- Lafayette, Louisiana

- Barry Wainscott, M.D., M.P.H.
- Assistant Health Director
- Jefferson County Health Department
- Louisville, Kentucky

- Barry W. Wall, M.S.
- State Methadone Administrator
- Office of Substance Abuse Services
- Richmond, Virginia

- D. Heather Watts, M.D.
- Associate Professor
- Department of Obstetrics/Gynecology
- University of Washington
- Seattle, Washington

- Ellen Weber, Esq.
- Codirector, National Policy
- Legal Action Center
- Washington, D.C.

- Robert B. Whitney, M.D.
- Head of Medical Services
- Research Institute on Alcoholism
- Buffalo, New York

- Lester N. Wright, M.D., M.P.H.
- Chairman, Department of Health Administration
- Department of Health Administration
- School of Public Health
- Loma Linda University
- Loma Linda, California

- Eddie Yamamoto
- Alcohol and Drug Program Analyst
- Department of Alcohol and Drug Programs
- State of California
- Sacramento, California