# Appendix B - Federal Resource Panel on Screening for Infectious Diseases Among Substance Abusers

- Andrea G. Barthwell, M.D.
- Chair, TIP Project
- Medical Director
- Interventions
- Chicago, Illinois

- Stuart M. Berman, M.D.
- Special Assistant for Perinatal and Adolescent Studies
- Clinical Research Branch
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Robert O. Cannon, M.D., M.P.H.
- Medical Epidemiologist
- Viral Studies Section
- Division of Sexually Transmitted Diseases/HIV Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Dorynne Czechowicz, M.D.
- Assistant Director for Medical and Professional Affairs
- Division of Clinical Research National Institute on Drug Abuse
- Rockville, Maryland

- Samuel W. Dooley, Jr., M.D.
- Medical Epidemiologist
- Division of Tuberculosis Elimination
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Paul A. DuCommun, R.N.
- formerly Senior Health Administrator, now retired
- Division of HIV Services
- Health Resources and Services Administration
- Rockville, Maryland

- Cynthia L. Gibert, M.D.
- Assistant Chief, Infectious Diseases
- Veterans Affairs Medical Center
- Washington, D.C.
- Assistant Professor of Medicine
- Georgetown University
- Washington, D.C.

- Harry W. Haverkos, M.D.
- Acting Director
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Warren W. Hewitt, Jr.
- Acting Director, Division of Clinical Programs
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Eugene Hurwitz, M.D.
- Deputy Chief, Hepatitis Branch
- Epidemiology Section
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- T. Stephen Jones, M.D.
- Director for Substance Abuse and HIV Prevention
- Office of the Associate Director for HIV/AIDS
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Mary Jeanne Kreek, M.D.
- Associate Professor and Physician
- Laboratory of the Biology of Addictive Diseases
- The Rockefeller University
- New York, New York

- Linda N. Lewis
- Assistant Deputy Director for Treatment and Rehabilitation
- Office of National Drug Control Policy
- Washington, D.C.

- Anna Marsh, Ph.D.
- Chief
- Quality Assurance and Evaluation Branch
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Janet L. Mitchell, M.D., M.P.H.
- Chief of Perinatology
- Harlem Hospital Center
- New York, New York

- Mark Parrino, M.P.A.
- President
- American Methadone Treatment Association, Inc.
- New York, New York

- Maureen Power, R.N., M.P.H.
- Nurse Consultant
- Division of AIDS
- National Institute of Allergy and Infectious Diseases
- National Institutes of Health
- Rockville, Maryland

- Raymond Seltser, M.D., M.P.H.
- Associate Director for Special Population Research
- Agency for Health Care Policy and Research
- Center for General Health Services Extramural Research
- Rockville, Maryland

- Pamela Stratton, M.D.
- Special Assistant for Obstetrics and Gynecology and Pediatrics
- Adolescent and Maternal AIDS Branch
- PAMA
- Center for Research for Mothers and Children
- National Institute of Child Health and Human Development
- Rockville, Maryland

- Raymond A. Strikas, M.D.
- Medical Epidemiologist
- Division of Immunization
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Cherry Y. Tsutsumida, M.P.H.
- Chief
- Area Health Education Centers and Special Projects Branch
- Health Resources and Services Administration
- Rockville, Maryland

- Ellen M. Weber, Esquire
- Codirector, National Policy
- Legal Action Center
- Washington, D.C.