# Chapter 6 - Summary Statement on Tuberculosis

Tuberculosis (TB) is a major public health problem both in the United States and worldwide. After 30 years of a declining incidence of new cases, in 1985 the number of new cases of TB began to increase in the United States; from 1985 to 1991, there was an 18 percent increase in the number of new cases. The greatest increases have occurred among young adult African Americans and Hispanics living in large cities. Increases have been noted among persons who are infected with the human immunodeficiency virus (HIV), many of whom are injection drug users. The increase in new cases is occurring primarily in areas with high rates of HIV/AIDS, i.e., urban areas with a large, poor, minority population. The rise in new cases of TB is closely linked to the HIV epidemic. In addition, an increase in outbreaks of TB in a variety of settings (correctional facilities, homeless shelters, nursing homes, hospitals, drug treatment centers) is also contributing to the increase of TB.

Major outbreaks of HIV-related TB involving transmission of multidrug-resistant organisms have been recently reported - reports that are alarming to the public health and medical communities. Multidrug-resistant tuberculosis (MDR-TB) is defined as a tuberculosis infection in which the TB isolate is at least resistant to isoniazid and rifampin, the best available anti-TB drugs. From 1990 through early 1992, the Centers for Disease Control and Prevention (CDC), in collaboration with State and local health departments, investigated outbreaks of MDR-TB in hospitals and correctional facilities in Florida and New York. More than 200 cases of MDR-TB have been identified through these investigations. In these outbreaks, a number of health care workers exposed to patients with MDR-TB have been diagnosed with active disease or have converted their tuberculin skin tests from negative to positive. MDR-TB progresses rapidly in HIV-positive patients, with from 72percent to89 percent dying within 4 to 16 weeks.

Without aggressive screening and prevention measures, patients and staff in drug treatment centers are at substantial risk of developing active TB and, in some geographic areas, MDR-TB. Drug treatment programs can undertake a number of measures that will reduce this risk. Lessons learned from the MDR-TB outbreak - as well as the recommendations of CDC - provide a guide on what drug treatment programs can do to prevent transmission of both TB and MDR-TB among their patients and staff.

## Characteristics of the MDR-TB Outbreaks

How did multidrug-resistant tuberculosis develop? Multiple reasons account for the increased incidence of MDR-TB, but several factors warrant comment. Drug resistance has developed primarily as a result of noncompliance with prescribed anti-TB therapy among patients with active tuberculosis. Many patients were started on appropriate therapy, but adequate and complete medical followup did not occur. Such followup must be consistently carried out to ensure ongoing compliance, completion of therapy, and successful outcomes. Failure to do this left many persons in the community with partially and unsuccessfully treated TB. This unsuccessfully treated population became the source of MDR-TB.

A second factor has been the failure of health care workers to suspect a case of active tuberculosis and rapidly isolate infectious TB patients. Patients who are not recognized as having active TB may expose other persons to the disease both in the hospital and in the community. Among HIV-infected persons, the consequences of failing to recognize possible exposure or active disease have been devastating. In addition, the absence of proper ventilation on hospital wards and in outpatient facilities, as well as in any of a number of other care facilities, has led to the spread of TB in hospitals, prisons, homeless shelters, and other settings.

### Delay in Diagnosis

Prompt diagnosis of TB was not always made in the initial MDR-TB outbreaks, because the majority of persons with MDR-TB were HIV-positive, and many had AIDS. The clinical presentation of TB in this population is frequently atypical: lung cavitation may not be present on chest radiographs, and sputums may not be smear-positive for acid-fast bacilli.

In addition, the diagnosis was frequently based only on TB sputum culture results. In most cases, at least 8 weeks had elapsed before culture results were obtained, and even more time had elapsed before drug-susceptibility results became available. Thus even when treatment for TB was started, it usually did not include adequate drugs.

### Inadequate Isolation Practices

Patients were not effectively isolated in health care settings. In many cases, doors to rooms of patients known to be infected with TB were not kept closed, health care workers and visitors did not wear masks or used masks improperly, and patients left their rooms without wearing masks. Many hospital isolation rooms did not have negative pressure relative to the hallways (i.e., the direction of air flow was from the isolation room to the hall. The airflow must be from the hall to the isolation room and then outside).

In addition, many HIV-infected persons were clustered on one ward or in large multibed rooms, and the infection was spread from patient to patient in the hospital.

### Exposure of Health Care Workers

Because of the failure to recognize, isolate, and adequately treat these MDR - TB cases, a substantial number of health care workers and prison guards who were exposed converted their tuberculin skin tests, indicating recent infection with TB. At least nine of these workers have developed active MDR - TB, and five of them have died.

## Prevention Efforts in Health Care Settings

The health care community is now charged with a series of critical tasks, including

- Limiting the spread of TB
- Screening for TB
- Educating the public about TB
- Developing improved strategies for earlier recognition of infection
- Providing supervised and appropriate care
- Making scientific advances that will enable earlier diagnosis as well as better therapies or vaccines

The Centers for Disease Control and Prevention has established guidelines for preventing the transmission of tuberculosis in health care settings. CDC guidelines are shown in table 1 . It is mandatory that drug treatment programs become familiar with these guidelines and implement them as necessary in their facilities. Health care facilities unable to comply with these guidelines should transfer any persons with suspected or active tuberculosis to an appropriate health care setting.

Table 1. CDC guidelines for preventing the transmission of tuberculosis in health care settings

I. Early Identification and Treatment of Active TB Cases

The following guidelines will help health care personnel in the early identification and treatment of persons with active TB.

- A high index of suspicion for TB should be maintained to identify cases rapidly.
- Prompt, effective multidrug therapy should be initiated; this therapy should be based on clinical and drug-resistance surveillance data relative to the given geographical region and population demographics.

II. Preventing the Spread of Infection

The spread of infectious droplet nuclei needs to be prevented by source control methods and by the reduction of microbial contamination of indoor air, using the following precautions.

- TB isolation precautions should be initiated immediately for all persons with suspected or confirmed active TB, since they may be infectious to others. Isolation precautions include placing the patient in a private room with negative pressure in relation to surrounding areas (i.e., air flow is from hallway into room and then to outdoors). The isolation room must have a minimum of six air exchanges per hour. Air from the room must be vented directly to the outside.
- To supplement proper ventilation, several other means to minimize exposure to TB should be considered. The use of disposable particulate respirators is recommended for staff members. These masks should be worn in clinic areas where aerosol treatments are given or sputum induction is done, as well as by hospital personnel in bronchoscopy suites and in patient isolation rooms. Patients should be instructed to cover their mouths when coughing or sneezing and to wear a mask when going out of isolation rooms.
- High-efficiency filtration systems may help reduce the risk of transmission, although their effectiveness has not been adequately evaluated in the clinical setting.
- Ultraviolet germicidal irradiation with UV-C in patient care areas, including outpatient clinics, may reduce the risk of transmission, although its effectiveness in the clinical setting has not been demonstrated.
- TB isolation precautions should be continued until the following conditions exist:
  - Three successive sputum samples obtained on different days are smear negative for AFB.
  - The patient has signs of clinical improvement.
  - The patient is receiving appropriate antituberculous therapy.
- Special respiratory and isolation precautions should be employed during any cough-inducing procedures (i.e., sputum induction; bronchoscopy; administration of aerosolized pentamidine to HIV-infected persons; nebulization treatment for asthma, emphysema; and when suctioning patients whether they are on a ventilator or not).

III. Surveillance for TB Transmission

Surveillance for TB transmission needs to be done to protect patients, health care workers, and visitors.

- Surveillance for TB infection should be maintained among health care workers by routine, periodic tuberculin skin testing every 6 to 12 months if there is no known exposure to a patient with active, untreated TB. Programs should recommend and follow up on appropriate preventive therapy for health care workers who meet the criteria for anti-TB prophylaxis. Immunocompromised health care workers, especially those with HIV/AIDS, may not convert their skin test and/or may be anergic. These workers need close medical followup.
- Ongoing surveillance for TB cases should be maintained among patients and health care workers.
- Contact investigation procedures need to be promptly initiated for any health care workers, patients, and visitors who are exposed to an untreated or ineffectively treated infectious TB patient who did not receive appropriate isolation and ongoing drug therapy. For infected contacts of infectious cases, appropriate anti-TB treatment or prophylaxis should be recommended. The initial therapeutic regimen should be based on the clinical history and on relevant, local drug-resistance surveillance data.

## Public Health Issues and Implications for the Future

The public health policy regarding diagnosis, isolation, and treatment of tuberculosis in the United States - both now and for the foreseeable future - is undergoing increasing scrutiny and reevaluation. New guidelines are being developed, and over the next few years the approach to issues concerning TB will be changing. There are a number of issues that must be addressed and dealt with at a national level. The following improvements are needed:

- Improved screening methods to detect persons with latent or active TB
- More rapid laboratory diagnosis of active TB
- More rapid drug susceptibility testing to facilitate the prescribing of the most effective combination therapies
- Development of new anti-tuberculosis drugs
- Development of vaccines
- Provision of the means to isolate persons with active tuberculosis who are in health care facilities or other congregate settings (such as correctional facilities) until drug-susceptibility test results are available and until appropriate therapy has been administered for a sufficient period of time to eliminate infectivity
- Provision of the means to ensure prompt treatment with appropriate therapy given in a supervised setting
- Identification of better and/or shorter courses of therapy for preventive therapy of persons with latent infection (i.e., those with a positive purified protein derivative (PPD) or who are infected but are anergic)
- Improved environmental methods to protect potentially exposed persons in living and work places where exposure is of concern
- Better contact tracing and followup
- Education to improve awareness of TB in both health care workers and the general public
- Possible reopening of TB sanitoriums for infected persons for whom adequate and complete therapy will be otherwise difficult.

To limit the spread of MDR-TB and to protect both at-risk patients and health care providers, it is essential that the medical community undertake a concerted and determined campaign to limit the spread of TB, including MDR-TB, as well as HIV infection. This mandate will be one of the principal public health policy challenges for this country during the 1990s.