# Definition of the Term "Drug Use"

The term "drug use" as used in this Treatment Improvement Protocol (TIP) encompasses the following categories of drugs:

- Cannabis (marijuana, hashish)
- Cocaine
- Hallucinogens (e.g., LSD, mescaline)
- Inhalants (e.g., gasoline, glue)
- Alcohol
- Opioids (e.g., heroin, pentazocine [Talwin], codeine)
- Phencyclidine (PCP)
- Sedatives, hypnotics, or anxiolytics (e.g., barbiturates, benzodiazepines)
- Stimulants (e.g., amphetamines)

Tobacco, considered to be a drug, is excluded from this discussion because it is only marginally relevant to the topic of this TIP.