# Consensus Panel Members

- Andrea G. Barthwell, M.D.
- Chair, TIP Project
- Medical Director
- Interventions
- Chicago, Illinois

- William A. Alexander, M.D.
- Associate Professor of Clinical Medicine
- Morehouse School of Medicine
- Atlanta, Georgia

- Lawrence S. Brown, Jr., M.D., M.P.H.
- Senior Vice President
- Division of Medical Services, Evaluation and Research
- Addiction Research and Treatment Corporation
- Brooklyn, New York
- Assistant Clinical Professor of Medicine
- Department of Medicine
- Harlem Hospital
- College of Physicians and Surgeons
- Columbia University
- New York, New York

- Milton Earl Burglass, M.D., M.P.H., M.Div., M.S.,C.A.S., F.A.A.F.P
- Zinberg Center for Addiction Studies
- Harvard Medical School
- Cambridge, Massachusetts

- Henry F. Chambers, M.D.
- Associate Professor of Medicine
- University of California at San Francisco
- San Francisco, California

- Luis E. Fundora, M.D.
- Medical Director
- Impact Drug and Alcohol Treatment Center
- Pasadena, California

- Monto Ho, M.D.
- Professor of Medicine, Microbiology, and Pathology
- Chair, Department of Infectious Diseases and Microbiology
- University of Pittsburgh
- Pittsburgh, Pennsylvania

- Nancy Lodl, B.S.N., C.A.C., M.S.
- Information Specialist
- National Association for Perinatal Addiction Research and Education
- Chicago, Illinois

- B. W. MacArmstrong
- Health Facilities Surveyor
- Alcoholism and Drug Abuse Division
- Department of Health and Social Services
- State of Alaska
- Anchorage, Alaska

- Lucia Meijer
- Administrator
- Assessment Center
- Seattle, Washington

- Janet L. Mitchell, M.D., M.P.H.
- Chief of Perinatology
- Harlem Hospital Center
- New York, New York

- Gloria J. Mouzon, M.D., F.A.A.F.P.
- Interventions/Crossroads Outpatient Services
- Chicago, Illinois

- Elizabeth Pugh
- Licensing Consultant
- Kansas Department of Social and Rehabilitative Services
- Alcohol and Drug Abuse Services
- Topeka, Kansas

- Norbert P. Rapoza, Ph.D.
- Director
- Immunology and Infectious Diseases
- American Medical Association
- Chicago, Illinois

- Peter A. Selwyn, M.D., M.P.H.
- Associate Director, AIDS Program
- Associate Professor of Medicine and Epidemiology and Public Health
- School of Medicine
- Yale University
- New Haven, Connecticut

- Larry Siegel, M.D.
- Medical Director
- ImmuneCare of Key West
- Key West, Florida

- David C. Thomasma, Ph.D.
- Director of Medical Humanities Program
- Loyola University of Chicago
- Strich School of Medicine
- Maywood, Illinois

- D. Heather Watts, M.D.
- Associate Professor
- Department of Obstetrics/Gynecology
- University of Washington
- Seattle, Washington

- Bruce M. Whyte, M.D.
- Medical Epidemiologist
- Division of Public Health
- Georgia Department of Human Resources
- Atlanta, Georgia