# Consensus Panel

Note: Information given indicates each participant's affiliation during the time the panel was convened and may no longer reflect the individual's current affiliation.

Chair
- Felipe González Castro, M.S.W., Ph.D.
  Professor
  Department of Psychology
  Arizona State University
  Tempe, AZ

Co-Chairs
- Loretta J. Bradley, M.A., Ph.D.
  Professor
  Department of Educational Psychology
  Texas Tech University
  Lubbock, TX
- Jacqueline P. Butler, M.S.W., CCDC, LISW
  Professor of Clinical Psychiatry
  Substance Abuse Division
  College of Medicine
  University of Cincinnati
  Cincinnati, OH
- Flanders Byford, M.S.W., LCSW
  Oklahoma City-County Health Department
  Oklahoma City, OK
- Ting-Fun May Lai, M.S.W., CSW, CASAC
  Director
  Chinatown Alcoholism Center
  Hamilton-Madison House
  New York, NY

Workgroup Leaders
- Virgil A. Gooding, Sr., M.A., M.S.W., LISC
  Clinical Director
  Foundation II, Inc.
  Cedar Rapids, IA
- Ford H. Kuramoto, D.S.W.
  President
  National Asian Pacific American Families Against Substance Abuse
  Los Angeles, CA
- Harry Montoya, M.A.
  President/Chief Executive Officer
  Hands Across Cultures
  Española, NM
- Onaje M. Salim, M.A., NCAC-II, CCS
  Director
  Cork Institute Southeast Addiction Technology Transfer Center
  Morehouse School of Medicine
  Atlanta, GA

Panelists
- Barbara Lee Aragon, M.S.W.
  Academic Fellow
  Department of Health Services
  North Highlands, CA
- Debra A. Claymore, M.Ed.Adm.
  D. Claymore & Associates, Inc.
  Loveland, CO
- E. Daniel Edwards, D.S.W.
  Director
  Ethnic Studies Program
  University of Utah
  Salt Lake City, UT
- Tonda L. Hughes, M.S.N., Ph.D., FAAN
  Associate Professor
  College of Nursing
  University of Illinois at Chicago
  Chicago, IL
- David Mathews, M.A., Ph.D.
  Director of Adult Services
  Kentucky River Community Care, Inc.
  Jackson, KY
- Anthony (Tony) Taiwai Ng, M.D.
  Consultant
  Washington, DC
- Barry Pilson, Ph.D.
  Adjunct Professor
  School of Social Work
  Tulane University
  Metairie, LA
- Rafaela R. Robles, Ed.D.
  Director
  Technology Transfer Center
  Caribbean Basin/Hispanic Addiction
  Centro de Estudios en Adicción
  Universidad Central del Caribe
  Bayamon, PR
- Gloria M. Rodriguez, D.S.W.
  Research Scientist
  Division of Addiction Services
  New Jersey Department of Health and Senior Services
  Trenton, NJ
- Ann S. Yabusaki, M.Ed., M.A., Ph.D.
  Director
  Coalition for a Drug-Free Hawaii
  Honolulu, HI