# Appendix K Acknowledgments

Numerous people contributed to the development of this Treatment Improvement Protocol (TIP), including the TIP Consensus Panel (page vii), the Knowledge Application Program (KAP) Expert Panel and Federal Government Participants (page ix), the Resource Panel (Appendix H), the Cultural Competence and Diversity Network Participants (Appendix I), and the Field Reviewers (Appendix J).

This publication was produced under KAP, a Joint Venture of The CDM Group, Inc. (CDM), and JBS International, Inc., for the Substance Abuse and Mental Health Services Administration's Center for Substance Abuse Treatment.

CDM KAP personnel included Rose M. Urban, M.S.W., J.D., LCSW, CCAC, CSAC, KAP Executive Project Director; Jessica L. Culotta, M.A., KAP Managing Project Co-Director and former Managing Editor; Susan Kimner, Former Managing Project Co-Director; Raquel Witkin, M.S., former Deputy Project Manager; Claudia A. Blackburn, Psy.D., Expert Content Director; Shel Weinberg, Ph.D., Senior Research/Applied Psychologist; J. Max Gilbert, M.A., Ph.D., Senior Editor/Writer; Deborah Steinbach, M.A., and Janet G. Humphrey, M.A., former Senior Editors/Writers; Claudia Askew, Catalina Bartlett, M.A., Angela Cross, Timothy Ferguson, M.A., Randi Henderson, and Susan Hills, Ph.D., Writers; Angela Fiastro, Junior Editor; Sonja Easley, former Editorial Assistant; Virgie D. Paul, M.L.S., Librarian; and Maggie Nelson, former Project Coordinator.