# Appendix J Field Reviewers

Note: Information given indicates each participant's affiliation during the time the review was conducted and may no longer reflect the individual's current affiliation.

- Alan J. Aller y, M.Ed., M.H.A.
  Director
  Student Health Services
  University of North Dakota
  Grand Forks, ND
- Deborah Altschul, Ph.D.
  Assistant Professor/Psychologist
  Mental Health Services Research and Evaluation Unit
  Adult Mental Health Division
  Hawaii Department of Health
  University of Hawaii
  Honolulu, HI
- Diana S. Amodia, M.D.
  Medical Director
  Substance Abuse Treatment Services
  Haight Ashbury Free Clinics, Inc.
  San Francisco, CA
- Ronald G. Black
  Director, Residential Group
  Drug Abuse Foundation
  Del Ray Beach, FL
- Patricia T. Bowman
  Probation Counselor
  Fairfax Alcohol Safety Action Program
  Fairfax, VA
- Rodolfo T. Briseno, M.D., M.P.H.
  Facilitator
  Worker's Assistance Program–Youth Advocacy
  Austin, TX
- Stephanie Brooks, M.S.W.
  Interim Director & Assistant Professor
  Programs in Couple & Family Therapy
  College of Nursing and Health Professions
  Drexel University
  Philadelphia, PA
- Jutta H. Butler, B.S.N., M.S.
  Public Health Advisor
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Flanders Byford, M.S.W., LCSW
  Licensed Clinical Social Worker
  Oklahoma City County Health Department
  Oklahoma City, OK
- Maria J. Carrasco, M.P.A
  Director
  Multicultural Action Center
  Arlington, VA
- Gerhard E. Carrier, Ph.D.
  Chair, Mental Health & Addiction Studies
  Department of Mental Health
  Alvin Community College
  Alvin, TX
- Carol J. Colleran, CAP, ICADC
  National Director of Older Adult Services
  Center of Recovery for Older Adults
  Hazelden Foundation/Hanley-Hazelden
  West Palm Beach, FL
- Cynthia C. Crone, APN, MNSC
  Executive Director
  Center for Addictions Research, Education, and Services
  College of Medicine, Department of Psychiatry and Behavior Health
  University of Arkansas for Medical Sciences
  Little Rock, AR
- John P. de Miranda, Ed.M.
  Executive Director
  National Association on Alcohol, Drugs, and Disability, Inc.
  San Mateo, CA
- Efrain R. Diaz, Ph.D., LCSW
  Program Supervisor
  Connecticut Department of Mental Health and Addiction Services
  Hartford, CT
- Dedric L. Doolin, M.P.A.
  Deputy Director
  Area Substance Abuse Council, Inc.
  Cedar Rapids, IA
- Donna Doolin, LCSW
  Director
  Division of Health Care Policy, Addiction & Prevention Services
  Kansas Department of Social and Rehabilitation Services
  Topeka, KS
- Lynn Dorman, Ph.D., J.D.
  President
  Creating Solutions
  Portland, OR
- Gayle R. Edmunds
  Director
  Indian Alcoholism Treatment Services
  Wichita, KS
- Michele J. Eliason, Ed.S., Ph.D.
  Associate Professor
  The University of Iowa
  Iowa City, IA
- Jill Shepard Erickson, M.S.W., ACSW
  Public Health Advisor
  Child and Family Branch
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Elena Flores, M.A., Ph.D.
  Associate Professor
  School of Education
  Counseling and Psychology Department
  University of California, San Francisco
  San Francisco, CA
- Jo Ann Ford, M.R.C.
  Assistant Director
  Substance Abuse Resources and Disability Issues
  School of Medicine
  Wright State University
  Dayton, OH
- Maria del Mar Garcia, M.S.W., M.H.S.
  Continuing Education Coordinator
  Caribbean Basin and Hispanic Addiction Centro de Estudios en Adicción
  Universidad Central del Caribe
  Bayamon, PR
- Virgil A. Gooding, Sr., M.A., M.S.W., LISC
  Clinical Director
  Foundation II, Inc.
  Cedar Rapids, IA
- Maya D. Hennessey, CRADC
  Women's Specialist
  Supervisor, Quality Assurance, Technical Assistance & Training
  Office of Special Programs
  Division of Substance Abuse
  Illinois Department of Human Services and Substance Abuse
  Chicago, IL
- Michael W. Herring, LCSW
  Wayne Psychiatric Associates, P.A.
  Goldsboro, NC
- Deborah J. Hollis, M.A.
  Administrator
  Office of Drug Control Policy
  Division of Substance Abuse and Gambling Services
  Michigan Department of Community Health
  Lansing, MI
- Ruth Hurtado, M.H.A.
  Public Health Advisor
  Center for Substance Abuse Treatment
  Division of Pharmacologic Therapies
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Ting-Fun May Lai, M.S.W., CASAC
  Director
  Chinatown Alcoholism Center
  Hamilton-Madison House
  New York, NY
- Tom Laws
  Talihina, OK
- Susan F. LeLacheur, M.P.H., PA-C
  Assistant Professor of Health Care Sciences
  The George Washington University
  Washington, DC
- Jeanne Mahoney
  Director
  Provider's Partnership-Women's Health Issues
  American College of Obstetricians and Gynecologists
  Washington, DC
- Michael Mobley, Ph.D., M.Ed.
  Assistant Professor in Counseling Psychology
  Department of Educational, School and Counseling Psychology
  University of Missouri–Columbia
  Columbia, MO
- Valerie Naquin, M.A.
  Vice President
  Planning and Development
  Cook Inlet
  Anchorage, AK
- Paul C. Purnell, M.S.
  President
  Social Solutions, LLC
  Potomac, MD
- Laura Quiros, M.S.W.
  Program Associate
  Program Planning & Development Department
  Palladia, Inc.
  New York, NY
- Melissa V. Rael, USPHS
  Senior Program Management Officer
  Co-Occurring and Homeless Branch
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Susanne R. Rohrer, R.N.
  Nurse Consultant
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Laurie J. Rokutani, Ed.S., NCC, CPP, MAC
  Training Coordinator
  Virginia Commonwealth University
  Mid-America Addiction Technology Transfer Center
  Richmond, VA
- LaVerne R. Saunders, B.S.N., R.N., M.S.
  Training Specialist and Consultant
  Dorrington & Saunders and Associates
  Framingham, MA
- Gary Q. Tester, MAC, CCDC III-E, OCPS II
  Director
  Ohio Department of Alcohol and Drug Addiction Services
  Columbus, OH
- Ralph Varela, M.S.W.
  Chief Executive Officer
  Pinal Hispanic Council
  Eloy, AZ
- Ming Wang, L.C.S.W.
  Program Manager
  Division of Substance Abuse and Mental Health
  Utah Department of Human Services
  Salt Lake City, UT
- Mike Watanabe, M.S.W.
  President and CEO
  Asian American Drug Abuse Program, Inc.
  Los Angeles, CA
- Debbie A. Webster
  Community Program Coordinator
  Best Practice Team
  Division of Mental Health, Developmental Disabilities, and Substance Abuse Services
  North Carolina Department of Health and Human Services
  Raleigh, NC
- Melvin H. Wilson, M.B.A., LCSW-C
  High Intensity Drug Trafficking Area Coordinator
  Maryland Division of Parole and Probation
  Baltimore, MD
- Ann S. Yabusaki, M.Ed., M.A., Ph.D.
  Director
  Coalition for a Drug-Free Hawaii
  Honolulu, HI