# Appendix I Cultural Competence and Diversity Network Participants

Note: Information given indicates each participant's affiliation during the time the network was convened and may no longer reflect the individual's current affiliation.

- Elmore T. Briggs, CCDC, NCAC II
  President/CEO
  SuMoe Partners
  Germantown, MD
  African American Workgroup Member
- Deion Cash
  Executive Director
  Community Treatment and Correction Center, Inc.
  Canton, OH
  African American Workgroup Member
- Magdalen Chang, Ph.D.
  Center Manager
  Haight Ashbury Free Clinics, Inc.
  San Francisco, CA
  Asian/Pacific Islander Workgroup Member
- Diana Yazzie Devine, M.B.A.
  Executive Director
  Native American Connections, Inc.
  Phoenix, AZ
  Native American Workgroup Member
- Terry S. Gock, Ph.D.
  Director
  Pacific Clinics Asian Pacific Family Center
  Rosemead, CA
  Asian/Pacific Islander Workgroup and Lesbian/Gay/Bisexual/Transgender Workgroup Member
- Renata J. Henry, M.Ed.
  Director
  Delaware Health and Social Services
  New Castle, DE
  African American Workgroup Member
- Adelaida F. Hernandez, M.A., LCDC
  Youth OSR Services Program Director
  S.C.A.N., Inc.
  Laredo, TX
  Hispanic/Latino Workgroup Member
- Ford H. Kuramoto, D.S.W.
  President
  National Asian Pacific American Families Against Substance Abuse
  Los Angeles, CA
  Asian/Pacific Islander Workgroup Member
- Victor Leo, M.S.W., LCSW
  Board Chair
  Asian/Pacific American Consortium on Substance Abuse
  Portland, OR
  Aging Workgroup Member and Asian/Pacific Islander Workgroup Member
- Harry Montoya, M.A.
  President/CEO
  Hands Across Cultures
  Espanola, NM
  Hispanic/Latino Workgroup Member
- Michael E. Neely, Ph.D., MFCC
  Administrator
  Integrated Care System
  Los Angeles, CA
  African American Workgroup Member
- Tam Khac Nguyen, M.D., CCJS, LMSW
  President
  Vietnamese Mutual Association, Inc.
  Polk City, IA
  Asian/Pacific Islander Workgroup Member
- Rick Rodriguez
  Manager/Counselor
  Services United
  Santa Paula, CA
  Hispanic/Latino Workgroup Member
- Mariela C. Shirley, Ph.D.
  Assistant Professor
  University of North Carolina at Wilmington
  Wilmington, NC
  Hispanic/Latino Workgroup Member