# Appendix H Resource Panel

Note: Information given indicates each participant's affiliation during the time the panel was convened and may no longer reflect the individual's current affiliation.

- Ana Anders, M.S.W., LICSW
  Senior Advisor
  Special Populations Office
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Candace Baker, Ph.D.
  Clinical Affairs Manager
  Lesbian, Gay, Bisexual, and Transgender Special Interest Group
  National Association of Alcoholism and Drug Abuse Counselors
  Alexandria, VA
- Carole Chrvala, Ph.D.
  Senior Program Officer
  Board on Neuroscience & Behavioral Health
  Institute of Medicine
  Washington, DC
- Christine Cichetti
  Drug Policy Advisor
  United States Department of Health and Human Services
  Washington, DC
- Cathi Coridan, M.A.
  Senior Director for Substance Abuse Programs
  National Mental Health Association
  Alexandria, VA
- Edwin M. Craft, Dr.P.H.
  Program Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Christina Currier
  Public Health Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Dorynne Czechowicz, M.D.
  Medical Officer
  Treatment Development Branch
  Division of Treatment Research and Development
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Janie B. Dargan
  Senior Policy Analyst
  Office of National Drug Control Policy
  Executive Office of the President
  Washington, DC
- James (Gil) Hill, Ph.D.
  Director
  Office of Rural Health and Substance Abuse
  American Psychological Association
  Washington, DC
- Hendree E. Jones, M.A., Ph.D.
  Assistant Professor
  CAP Research Director
  Department of Psychiatry and Behavioral Sciences
  Johns Hopkins University Center
  Baltimore, MD
- Guadelupe Pacheco, M.P.A.
  Special Assistant to the Deputy Assistant Secretary
  Office of Minority Health
  Department of Health and Human Services
  Rockville, MD
- Cecilia Rivera-Casale, Ph.D.
  Senior Project Officer
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Deidra Roach, M.D.
  Health Science Administrator
  National Institute on Alcohol Abuse and Alcoholism
  Bethesda, MD
- Kevin Shipman, M.H.S., LPC
  Deputy Chief
  Grants and Program Management Division
  Special Population Services
  Washington, DC
- Richard T. Suchinsky, M.D.
  Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
  Mental Health and Behavioral Sciences Services
  Department of Veterans Affairs
  Washington, DC
- Jan Towers, Ph.D.
  Director
  Health Policy
  American Academy of Nurse Practitioners
  Washington, DC
- Jose Luis Velasco
  Project Director
  National Hispanic Council on Aging
  Washington, DC
- Karl D. White, Ed.D.
  Public Health Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Jeanean Willis, D.P.M., CDR, USPHS
  Public Health Analyst
  Office of Minority Health
  Health Resources and Services Administration
  Rockville, MD