# Links to Selected Abstracts and Books

## Selected Abstracts

Amendah D, Grosse S, Bertrand J. Medical expenditures of children in the united states with fetal alcohol syndrome. Neurotoxicology and Teratology. 2011;33(2):322-4. Retrieved from: http://www.ncbi.nlm.nih.gov/pubmed/21073947. [pmid: 21073947].
Astley SJ, Aylward EH, Olson HC, Kerns K, Brooks A, Coggins TE, Richards T. Magnetic resonance imaging outcomes from a comprehensive magnetic resonance study of children with fetal alcohol spectrum disorders. Alcoholism: Clinical and Experimental Research. 2009;33(10):1-1. Retrieved from: http://depts.washington.edu/fasdpn/pdfs/astley-mri.pdf.
Astley SJ. Profile of the first 1,400 patients receiving diagnostic evaluations for fetal alcohol spectrum disorder at the Washington State Fetal Alcohol Syndrome Diagnostic and Prevention Network. Canadian J Clinical Pharmacology Winter. 2010;17(1):e132-164. Retrieved from: http://depts.washington.edu/fasdpn/pdfs/astley-profile-2010.pdf.
Bertrand J, Floyd RL, Weber MK, O'Connor M, Riley EP, Johnson KA, Cohen DE. 2004. National Task Force on Fetal Alcohol Syndrome and Fetal Alcohol Effect. Fetal Alcohol Syndrome: Guidelines for Referral and Diagnosis. Atlanta, GA. Centers for Disease Control and Prevention (CDC). Retrieved from: http://www.cdc.gov/ncbddd/fasd/documents/fas_guidelines_accessible.pdf.
Bertrand J. Interventions for children with Fetal Alcohol Spectrum Disorders (FASD): Overview of findings for five innovative research projects. Res Dev Disabil. 2009;30(5):986-1006. Retrieved from: http://www.ncbi.nlm.nih.gov/pubmed/19327965?log$=activity. [pmid: 19327965].
Centers for Disease Control and Prevention. Fetal alcohol syndrome —Alaska, Arizona, Colorado, and New York, 1995–1997. MMWR. 2002;51(20):433-5. Retrieved from: http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5120a2.htm. [pmid: 12056499].
Chudley AE, Conry J, Cook JL, Loock C, Rosales T, Leblanc N. Fetal alcohol spectrum disorder: Canadian guidelines for diagnosis. CMAJ. 2005;172(5 Suppl.):S1-S21. Retrieved from: http://www.canadianmedicaljournal.ca/content/172/5_suppl/S1.short. [pmid: 15738468].
Hoyme HE, May PA, Kalberg WO, Kodituwakku P, Gossage JP, Trujillo PM, Robinson LK. A practical clinical approach to diagnosis of fetal alcohol spectrum disorders: Clarification of the 1996 Institute of Medicine criteria. Pediatrics. 2005;115(1):39-47. Retrieved from: http://www.ncbi.nlm.nih.gov/pmc/articles/PMC1380311/. [pmid: 15629980].
Interagency Coordinating Committee on Fetal Alcohol Spectrum Disorders. 2011. Consensus Statement Recognizing Alcohol-Related Neurodevelopmental Disorder (ARND) in Primary Health Care of Children. Rockville, Maryland. National Institute on Alcohol Abuse and Alcoholism. Retrieved from: http://www.niaaa.nih.gov/sites/default/files/ICCFASD_ARNDProgram_D_508.pdf.
Kelly SJ, Day N, Streissguth AP. Effects of prenatal alchol exposure on social behavior in humans and other species. Neurotoxicol Teratol. 2000;22:143-149. Retrieved from: http://www.ncbi.nlm.nih.gov/pubmed/10758343. [pmid: 10758343].
Knight J, Shrier L, Barvender T, Farrell M, Vander Bilt J, Shaffer HJ. A new brief screen for adolescent substance abuse. Arch Pediatr Adolesc Med. 1999;153(6):591-596. Retrieved from: http://www.ncbi.nlm.nih.gov/pubmed/10357299. [doi: 10.1001/archpedi.153.6.591]. [pmid: 10357299].
Lupton C, Burd L, Harwood R. Cost of fetal alcohol spectrum disorders. American Journal of Medical Genetics. 2004;127c(671):42-50. Retrieved from: http://onlinelibrary.wiley.com/10.1002/ajmg.c.30015/abstract. [pmid: 15095471].
Mattson SN, Schoenfeld AM, Riley EP. Teratogenic effects of alcohol on brain and behavior. Alcohol Res Health. 2001;25(3):185-191. Retrieved from: http://pubs.niaaa.nih.gov/publications/arh25-3/185-191.htm. [pmid: 11810956].
May PA, Gossage JP, Kalberg WO, Robinson LK, Buckley D, Manning M, Hoyme HE. Prevalence and epidemiologic characteristics of FASD from various research methods with an emphasis on recent in-school studies. Dev Disabil Res Rev. 2009;15(3):176-192. Retrieved from: http://www.ncbi.nlm.nih.gov/pubmed/19731384. [pmid: 19731384].
Russell M. New assessment tools for drinking in pregnancy: T-ACE, TWEAK, and others. Alcohol Health and Research World. 1994;18(1):55-61. Retrieved from: http://www.ncbi.nlm.nih.gov/pubmed/2712118.
Sokol RJ, Martier S, Ager JW. The T-ACE Questions: Practical prenatal detection of risk-drinking. American Journal of Obstetrics and Gynecology. 1989;150(4):863-868. Retrieved from: http://www.ncbi.nlm.nih.gov/pubmed/2712118. [pmid: 2712118].

## Selected Books

Astley SJ, Clarren SK. 1997. Diagnostic Guide for Fetal Alcohol Syndrome and Related Conditions; The 4-digit Diagnostic Code. University of Washington Press. Seattle, Washington.
Astley SJ. 2004. Diagnostic guide for fetal alcohol spectrum disorders: The 4-digit diagnostic code. Seattle, Washington. University of Washington.
Clarren S, Salmon A, Jonsson E, editors. 2011. Prevention of Fetal Alcohol Spectrum Disorder FASD: Who is responsible?. Weinheim, Germany. Wiley-VCH Verlag & Co.
Riley EP, Clarren S, Weinberg J, Jonsson E, editors. 2011. Fetal Alcohol Spectrum Disorder: Management and Policy Perspectives of FASD. Weinheim, Germany. Wiley-VCH Verlag & Co.
Spohr HL, Steinhausen HC, editors. 1996. Alcohol, Pregnancy and the Developing Child. New York. Cambridge University Press.
Stratton K, Howe C, Battaglia F, editors. 1996. Fetal Alcohol Syndrome: Diagnosis, Epidemiology, Prevention, and Treatment. Washington, DC. National Academy Press.
Streissguth AP, Barr JK, Bookstein FL. 1996. Understanding the Occurrence of Secondary Disabilities in Clients with Fetal Alcohol Syndrome (FAS) and Fetal Alcohol Effects (FAE). Seattle. University of Washington, Fetal Alcohol and Drug Unit.
Streissguth AP, Kanter J, editors. 1997. The Challenge of Fetal Alcohol Syndrome: Overcoming Secondary Disabilities. Seattle, WA. University of Washington Press.