# Administrator's Guide to Implementing FASD Prevention and Intervention

Introduction

Chapter 1 The Administrative Response to FASD in Behavioral Health Settings

Chapter 2 Building an FASD Prevention- and Intervention-Capable Agency