# Background and Clinical Strategies for FASD Prevention and Intervention

Chapter 1 Prevention of Alcohol-Exposed Pregnancies Among Women of Childbearing Age

Chapter 2 Addressing FASD in Treatment

Chapter 3 Clinical Vignettes