# Consensus Panel

Chairs, Part 1 and Part 2 Consensus Panels
- Sterling K. Clarren, M.D., FAAP
  Chief Executive Officer and Scientific Director
  Canada NW FASD Research Network, Vancouver, British Columbia
  Clinical Professor of Pediatrics
  University of British Columbia, Vancouver, British Columbia
  Clinical Professor of Pediatrics
  University of Washington, Seattle, Washington
- Melinda Ohlemiller, M.A.
  Chief Executive Officer
  Nurses for Newborns Foundation
  St. Louis, Missouri

Part 1 Consensus Panel Members
- Susan Adubato, Ph.D.
  Director
  Northern New Jersey FAS Diagnostic Center, Newark, New Jersey
  Director
  New Jersey/North East FASD Education and Research Center
  University of Medicine and Dentistry of New Jersey
  New Jersey Medical School, Newark, New Jersey
- Mercedes Alejandro
  FASD Prevention Advocate
  The Arc of Greater Houston
  Houston, Texas
- Mary C. DeJoseph, D.O.
  Adjunct Faculty
  Philadelphia College of Osteopathic Medicine
  Palmyra, New Jersey
- Norma Finkelstein, Ph.D., LICSW
  Executive Director
  Institute for Health and Recovery
  Cambridge, Massachusetts
- Therese Grant, Ph.D.
  Ann Streissguth Endowed Professor in Fetal Alcohol Spectrum Disorders
  University of Washington School of Medicine
  Director, Washington State Parent-Child Assistance Program
  Seattle, Washington
- Patricia Moran
  Program Manager
  White Earth Substance Abuse Program
  Ponsford, Minnesota
- Mark B. Sobell, Ph.D., ABPP
  Professor /& Co-Director
  Healthy Lifestyles Guided Self-Change Program
  Center for Psychological Studies
  Nova Southeastern University
  Fort Lauderdale, Florida
- Jasmine Suarez-O'Connor
  Network Coordinator
  Self Advocates with FASD in Action (SAFA)
  Scotia, New York
- Diane L. O'Connor
  FASD Prevention Initiative
  Research Foundation of Mental Hygiene
  Support Person
  Self Advocates with FASD in Action
  Albany, New York

Part 2 Consensus Panel Members
- Hortensia Amaro, Ph.D.
  Hortensia Amaro, Ph.D.
  Associate Dean and Distinguished Professor
  Bouve College of Health Sciences
  Director, Institute on Urban Health Research
  Northeastern University
  Boston, Massachusetts
- L. Diane Casto, M.P.A.
  Manager
  Behavioral Health, Prevention & Early Intervention Services
  Alaska Department of Health and Social Services
  Juneau, Alaska
- Deborah E. Cohen, Ph.D.
  Director
  Office for Prevention of Mental Retardation and Developmental Disabilities
  State of New Jersey (Retired)
- Norma Finkelstein, Ph.D., LICSW
  Executive Director
  Institute for Health and Recovery
  Cambridge, Massachusetts
- Sidney L. Gardner, M.P.A.
  President
  Children and Family Futures
  Irvine, California
- Pamela Gillen, N.D., R.N., CACIII
  Director
  Colorado FASD/ATOD Substances Prevention Outreach Project (COFAS)
  University of Colorado at Denver
  Aurora, Colorado
- Logan Lewis, LMSW, CASAC
  Clinical Director
  Camelot Counseling
  Jamaica, New York
- Donna N. McNelis, Ph.D.
  Director, Behavioral Healthcare Education
  Vice-Chair, Program Development & Administration
  Professor of Psychiatry
  Drexel University College of Medicine
  Philadelphia, Pennsylvania
- Sara Messelt
  Executive Director
  Minnesota Organization on Fetal Alcohol Syndrome (MOFAS)
  St. Paul, Minnesota
- Heather Carmichael Olson, Ph.D.
  Department of Psychiatry and Behavioral Sciences
  University of Washington School of Medicine
  Seattle Children's Hospital Child Psychiatry Outpatient Clinic
  Fetal Alcohol Syndrome Diagnostic and Prevention Network
  Seattle Children's Hospital Research Institute
  Families Moving Forward Program
  Seattle, Washington
- Deborah Stone, Ph.D.
  Social Science Analyst
  Center for Mental Health Services (CMHS)
  Rockville, Maryland (Retired)