# Acknowledgments

Numerous people contributed to the development of this TIP, including the TIP Consensus Panelists (see pp. ix-x), Stakeholder meeting attendees (see Appendix I) and field reviewers (see Appendix J).

This publication was produced under the Fetal Alcohol Spectrum Disorders (FASD) Center for Excellence contract with the Northrop Grumman Corporation, for the Substance Abuse and Mental Health Services Administration, Center for Substance Abuse Prevention.

Callie B. Gass served as the FASD Center for Excellence Project Director, and Sharon James Ackah, J.D., M.P.H., served as the Deputy Project Director. Other Northrop Grumman-FASD Center for Excellence personnel included Dan Dubovsky, M.S.W., LCSW, Senior FASD Specialist; Vinitha Meyyur, Ph.D., Senior Evaluator and TIP Task Manager; Susan Kimner, Manager for Product Development; Jason P. Merritt, M.A., Senior Writer; Barbara Kosogof, M.P.A., and Katie Chan, Health Research Analysts and Literature Review Authors; Sharon J. Lytle, Quality Assurance Editor; and Jennifer Aggelis, Graphic Designer.