# Field Reviewers

- Susan Adubato, Ph.D.
  Director, Northern New Jersey FAS Diagnostic Center
  Director, New Jersey/North East FASD Education and Research Center, University of Medicine and Dentistry of New Jersey, New Jersey Medical School
  Newark, NJ
- Sally Anderson, Ph.D.
  Special Assistant to Deputy Director
  National Institute on Alcohol Abuse and Alcoholism
  Rockville, MD
- Susan Astley, Ph.D.
  Professor of Epidemiology/Pediatrics, University of Washington
  Director, WA State FAS Diagnostic & Prevention Network
  Seattle, WA
- Michael Baldwin, M.N.S.
  Alaska Mental Health Trust Authority
  Anchorage, AK
- Jacqueline Bertrand, Ph.D.
  Psychologist
  Centers for Disease Control and Prevention
  Atlanta, GA
- Eileen B. Bisgard, J.D.
  Project Director
  Seventeenth Judicial FASD Project
  Brighton, CO
- Anthony Bullock
  Hattiesburg, MS
- Janet S. Burtt, M.A.
  Southern California Alcohol & Drug Programs, Inc.
  Downey, CA
- Melissa Clarke
  Lissie's Luv Yums
  Great Falls, MT
- Deborah E. Cohen, Ph.D.
  Director, Office for Prevention of Mental Retardation and Developmental Disabilities, State of New Jersey (Retired)
  Longboat Key, FL
- Randolph Crawford
  Norman, OK
- Leah Davies
  TOPDD
  Austin, TX
- Mary DeJoseph, D.O.
  Doctor
  New Jersey FASD Education and Research Center
  Palmyra, NJ
- Thomas Ebert, M.S.S.W., Ph.D.
  ARC Community Services, Inc.
  Madison, WI
- Louise Floyd, R.N., D.S.N.
  Team Leader/Behavioral Scientist
  Fetal Alcohol Syndrome Prevention Team
  National Center for Birth Defects and Developmental Disabilities
  Centers for Disease Control and Prevention
  Atlanta, GA
- Sid Gardner, M.P.A.
  President
  Children and Family Futures
  Irvine, CA
- Julie Gelo
  Trainer/Consultant/Advocate/Parent
  Executive Director, NOFAS Washington
  Support Person, Self Advocates with FASD in Action
  Bothell, WA
- Linda Grant
  Evergreen Manor
  Everett, WA
- Therese Grant, Ph.D.
  Ann Streissguth Endowed Professor in Fetal Alcohol Spectrum Disorders Director, Fetal Alcohol and Drug Unit
  University of Washington School of Medicine
  Seattle, WA
- Cecily Hardin, M.S.W.
  FASD Project Coordinator
  Child Guidance Center
  Jacksonville, FL
- Patricia A. Harrison, Ph.D.
  Research Director
  Minneapolis, MN
- Trisha Hinson, M.Ed., CMHT
  FASD State Coordinator/Project Director
  Mississippi Department of Mental Health
  Brandon, MS
- Sr. Johnelle Howanach
  Lissie's Luv Yums
  Great Falls, MT
- Catherine Hutsell, M.P.H.
  Health Education Specialist
  FAS Prevention Team
  National Center on Birth Defects and Development Disorders
  Centers for Disease Control and Prevention
  Atlanta, GA
- Wendy O. Kalberg, M.A., CED
  Senior Program Manager
  UNM CASAA
  Albuquerque, NM
- Judith King, M.S.W., LCSW, LCADC, CPAS
  Coordinator, Perinatal Addictions Prevention Project
  Hudson Perinatal Consortium, Inc.
  Jersey City, NJ
- Suzie Kuerschner, M.Ed.
  FASD Consultant and Trainer
  Northwest Portland Area Indian Health Board
  Rhododendron, OR
- John H. McGovern, M.G.A.
  Senior Public Health Analyst
  Health Resources and Services Administration
  Rockville, MD
- Sara Messelt
  Executive Director
  Minnesota Organization on FAS (MOFAS)
  St. Paul, MN
- Violet Mitchell-Enos, M.S.W.
  Scottsdale, AZ
- Patricia Moran
  Program Manager
  White Earth Substance Abuse Program
  Ponsford, MN
- Jeri Museth
  Wellness Coordinator, Tribal Family and Youth Services
  Central Council of the Tlingit and Haida Indian Tribes of Alaska
  Juneau, AK
- Raquelle Myers
  Santa Rosa, CA
- Diane O'Connor
  FASD Prevention Initiative, Research Foundation of Mental Hygiene
  Support Person, Self Advocates with FASD in Action (SAFA)
  Albany, NY
- Heather Carmichael Olson, Ph.D.
  Department of Psychiatry and Behavioral Sciences
  University of Washington School of Medicine and Seattle Children's Research Institute
  Seattle, WA
- Carol Rangel
  FASD Project Director
  Division of Health and Human Services
  Arkansas Division of Child and Family Services
  Little Rock, AR
- Jamie Reinebold, M.S.W.
  Supervisor, FACES
  Memorial Health System
  South Bend, IN
- Julia Robbins
  Institute for Health and Recovery
  Cambridge, MA
- Paulette Romashko, M.S.W., LCSW
  Director of Program Development and Evaluation
  FASD Project Director
  ARC Community Services, Inc.
  Madison, WI
- Iris Smith, Ph.D., M.P.H.
  Clinical Associate Professor
  Department of Behavioral Sciences and Health Education
  Rollins School of Public Health
  Atlanta, GA
- Brenda Stoneburner, M.A., LPC
  Communicable Disease Specialist
  Michigan Department of Health
  Bureau of Substance Abuse and Addiction
  Lansing, MI
- Sue Taylor, M.S.
  Manager Early Childhood Services
  Memorial Health System
  South Ben, IN
- Tracey Waller, M.B.A., RD, LD
  Bellbrook, OH
- Mary Kate Weber, M.P.H.
  Behavioral Scientist
  Fetal Alcohol Syndrome Prevention Team
  National Center on Birth Defects and Developmental Disabilities
  Centers for Disease Control and Prevention
  Atlanta, GA
- Nancy Whitney, M.S., LMHC
  Clinical Director, King County Parent Child Assistant Program
  University of Washington
  Seattle, WA
- Georgiana Wilton, Ph.D.
  Associate Scientist, Family Medicine
  University of Wisconsin
  Madison, WI
- Barbara Wybrecht, R.N.
  FASD Clinical Nurse Specialist
  Advocate/Trainer
  Support Person, Self Advocates with FASD in Action
  Grand Rapids, MI
- Rob Wybrecht
  Lifelong Expert on FASD
  Arc of Kent County
  Network Coordinator, Self Advocates with FASD in Action (SAFA)
  Grand Rapids, MI