# Stakeholders Meeting Participants

- Sally Anderson, Ph.D.
  Special Assistant to Deputy Director, National Institute on Alcohol Abuse and Alcoholism
- Jacquelyn Bertrand, Ph.D.
  Behavioral Scientist, Centers for Disease Control and Prevention
- Sterling K. Clarren, M.D., FAAP
  Chief Executive Officer and Scientific Director, Canada NW FASD Research Network; Clinical Professor of Pediatrics, University of British Columbia; Clinical Professor of Pediatrics, University of Washington; TIP Co-Chair
- Carolyn Hartness
  FASD Project Specialist, Northwest Portland Area Indian Health Board
- Lynne Haverkos, M.D., M.P.H.
  Medical Officer, National Institute of Child Health and Human Development
- John H. McGovern, M.G.A.
  Senior Public Health Analyst, Health Resources and Services Administration
- Sara Messelt
  Executive Director, Minnesota Organization on Fetal Alcohol Syndrome
- Kathleen Mitchell, M.H.S., LCADC
  Vice President and National Spokesperson, National Organization on Fetal Alcohol Syndrome
- Melinda M. Ohlemiller, M.A.
  Chief Executive Officer, Nurses for Newborns Foundation; TIP Co-Chair
- Feng Zhou, Ph.D.
  Past President, FASD Study Group; Professor, Indiana University School Medicine

Center for Substance Abuse Treatment
- Sharon Amatetti, M.P.H.
  Public Health Analyst, Division of Services Improvement, Center for Substance Abuse Treatment
- Christina Currier
  Project Officer, CSAT Knowledge Application Program, Division of Services Improvement, Center for Substance Abuse Treatment
- Richard T. Kopanda, M.A.
  CSAT Deputy Director, Center for Substance Abuse Treatment
- Linda White-Young, M.S.W., LC SW
  Public Health Advisor, Division of Services Improvement, Center for Substance Abuse Treatment

Center for Substance Abuse Prevention
- Jon Dunbar-Cooper, M.A., CPP
  Task Order Officer, SAMHSA FASD Center for Excellence, Division of Systems Development, Center for Substance Abuse Prevention
- Patricia Getty, Ph.D.
  Deputy Task Order Officer, SAMHSA FASD Center for Excellence, Division of Systems Development, Center for Substance Abuse Prevention
- CDR Josefine Haynes-Battle, R.N., B.S.N., M.S.N.
  Past Deputy Task Order Officer, SAMHSA FASD Center for Excellence, Division of Systems Development, Center for Substance Abuse Prevention
- Mike Lowther, M.A.
  Acting Deputy Director, Center for Substance Abuse Prevention
- Virginia Mackay-Smith, M.P.H.
  Director, Division of Systems Development, Center for Substance Abuse Prevention

Center for Mental Health Services
- Anna Marsh, Ph.D.
  Deputy Director, Center for Mental Health Services
- Deborah Stone, Ph.D.
  Social Science Analyst, Center for Mental Health Services (Retired)