# Services and Supports Checklist

Counselors can provide invaluable assistance to the family/caregivers of an individual who has or may have an FASD, or to their client with FASD, by helping them access appropriate services and supports. Below is a comprehensive checklist that can help a counselor and client identify what supports are needed, and choose what community resources are realistic as linkages.

If you have access to an electronic version of the TIP, consider printing this and the following page back-to-back to use with clients as an efficient worksheet. This form has been adapted from materials in the Families Moving Forward Program (http://depts.washington.edu/fmffasd). Check their Web site for more resources.

Services and Supports Checklist