# Part 3. Literature Review

Part 3, Section 1 Literature Review

Part 3, Section 2 Links to Selected Abstracts and Books

Part 3, Section 3 General Bibliography