# Public and Professional Resources on FASD

## The SAMHSA FASD Center for Excellence

SAMHSA FASD Center for Excellence www.fasdcenter.samhsa.gov
The official site of the SAMHSA FASD Center for Excellence provides information and resources about FASD, as well as awareness materials, a fully searchable database, and access to training, technical assistance, and conference/event speakers.
National Association of FASD State Coordinators http://fasdcenter.samhsa.gov/statesystemsofcare/nafsc.aspx
The SAMHSA FASD Center for Excellence helped to establish the National Association of FASD State Coordinators (NAFSC) in 2003 to support state-based efforts to increase the system of care available to individuals with an FASD and their families. NAFSC's mission is to promote prevention, treatment, and care systems for FASD, nationwide, through collaboration with systems within their respective states and among member states. The site provides updates on current activities, a roster of current members, and full contact information.

## Assessment and Diagnosis

National Organization on FAS (NOFAS) www.nofas.org
NOFAS is a leading voice and resource for the FASD community, and was one of the first. Founded in 1990, NOFAS is still the only international non-profit organization committed solely to FASD primary prevention, advocacy, and support. NOFAS has 30 affiliate programs around the country, and provides a Resource Directory to help locate FASD-related services. Also see Information and Training, below.
University of Washington: FAS Diagnostic & Prevention Network http://depts.washington.edu/fasdpn/
The Washington State FAS Diagnostic & Prevention Network (FAS/DPN) is a network of four WA State community-based interdisciplinary FASD diagnostic clinics linked by the core clinical/research/training clinic at the Center on Human Development and Disability at the University of Washington in Seattle. The network was established in 1993. Each clinic in the network uses the same interdisciplinary approach to diagnosis and the same systematic diagnostic method; the 4-Digit Diagnostic Code. The mission of the FAS DPN is primary and secondary prevention of FAS through screening, diagnosis, intervention, training, education, and research. The FAS DPN began diagnosing patients in 1993, and has diagnosed over 2,000 patients to date. See also Information and Training, below.

## Grant Opportunities

SAMHSA Grant Opportunities http://www.samhsa.gov/grants/
SAMHSA's grant management site allows applicants and prospective applicants to review Requests for Application (RFA's) from each of SAMHSA's sub-agencies, submit applications online, track application status, review reporting requirements, and manage the activity of awarded grants.
Grants.gov www.grants.gov
Grants.gov was established as a governmental resource named the E-Grants Initiative, part of the President's 2002 Fiscal Year Management Agenda to improve government services to the public. Today, Grants.gov is a central storehouse for information on over 1,000 grant programs and provides access to approximately $500 billion in annual awards. The site is searchable by agency, keyword, and a variety of other variables.

## Information and Training

Families Moving Forward http://depts.washington.edu/fmffasd/
The Families Moving Forward Program intervention is a scientifically validated behavioral consultation program tailored for families raising preschool and school-aged individuals with FASD or confirmed prenatal alcohol exposure. The intervention includes methods and materials that appropriately trained counselors can use when working with families of a client who has an FASD. Training on FASD intervention, and on the Families Moving Forward Program, is regularly available through the East Coast (Florida) or West Coast (Seattle) training centers, or on-site at an agency location in the United States, Canada, or elsewhere. Once training is completed, all materials are freely available on a Web site to be downloaded.
The FASD Information Page of the Centers for Disease Control and Prevention (CDC) http://www.cdc.gov/ncbddd/fasd/
The CDC's FASD page offers extensive information on the background of FASD, diagnosis and treatment, and training and educational materials, as well as access to articles, print materials, and multimedia tools for raising awareness.
FASD Regional Training Centers http://www.cdc.gov/ncbddd/fasd/index.html
The CDC's FASD Regional Training Centers (RTCs) develop, implement, and evaluate educational curricula regarding FASD prevention, identification, and care, and incorporate the curricula into training programs at each grantee's university or college, into other schools throughout their regions, and into the credentialing requirements of professional boards. Check the site for links to specific, currently-active regional sites. Currently funded regional sites include the following:; - Southeastern FASD Regional Training Center (http://www.fasdsoutheast.org/); - Arctic FASD Regional Training Center (http://www.uaa.alaska.edu/arcticfasdrtc/); - Frontier FASD Regional Training Center (http://www.frfasd.org/)
The National Institute on Alcohol Abuse and Alcoholism http://www.niaaa.nih.gov
The National Institute on Alcohol Abuse and Alcoholism (NIAAA) is one of the 27 Institutes and Centers that comprise the National Institutes of Health (NIH), a component of HHS. NIAAA is the primary U.S. agency for conducting and supporting research on the causes, consequences, prevention, and treatment of alcohol abuse, alcoholism, and alcohol problems, including health effects such as FASD. NIAAA disseminates research findings to general, professional, and academic audiences. The Web site has links to relevant NIAAA publications. The FASD-specific Web link (http://www.niaaa.nih.gov/research/major-initiatives/fetal-alcohol-spectrum-disorders)) at NIAAA is http://www.niaaa.nih.gov/research/major-initiatives/fetal-alcohol-spectrum-disorders. This page also links to overviews of the activities of NIAAA's Interagency Coordinating Committee on FASD (ICCFASD).
National Organization on FAS (NOFAS) www.nofas.org
NOFAS is a leading voice and resource for the FASD community, and was one of the first. Founded in 1990, NOFAS is still the only international non-profit organization committed solely to FASD primary prevention, advocacy, and support. The official site provides access to materials for educators, healthcare professionals, expectant mothers, and individuals and families living with an FASD. Also see Assessment and Diagnosis, above.
University of Washington FAS/DPN Training http://depts.washington.edu/fasdpn/htmls/training.htm
In addition to assessment and diagnostic services, the University of Washington's FAS/DPN offers 1-day trainings on screening, diagnosis, treatment planning, and primary prevention of FASD, and also 2-day and online trainings for interdisciplinary clinical teams (or individual clinical team members) seeking to establish a FASD Diagnostic Clinic in their community.

## Research and Journal Articles

Appendix A of this TIP contains an extensive bibliography for further reading on FASD, and Part 3 of this TIP, the online Literature Review (http://store.samhsa.gov/home), contains its own bibliography. In addition, the following Web sites and journals are excellent resources for further literature on FASD and related issues.
Alcohol http://www.sciencedirect.com/science/journal/07418329/44/7-8
In 2010, the journal Alcohol published two issues devoted entirely to FASD diagnosis and intervention (Volume 44, issues 7-8). Together, these issues contain 16 articles, all of which can be accessed via the link above. Note: There is a cost for each article.
The Collaborative Initiative on FASD (CIFASD) http://cifasd.org/
The Collaborative Initiative on FASD (CIFASD) is a consortium dedicated to informing and developing effective interventions and treatment approaches for FASD through multidisciplinary research involving basic, behavioral, and clinical investigators and projects. The Web site contains an extensive bibliography of recent FASD-related literature (2004 to the present). Many of the bibliographic items link to full abstracts through PubMed, but full articles must be purchased.
The Journal of Psychiatry & Law http://www.federallegalpublications.com/journal-of-psychiatry-law/
The Winter 2010 (Volume 38, issue 4 (http://www.federallegalpublications.com/journal-of-psychiatry-law/201106/jpl-2010-38-4-journal-of-psychiatry-law)) and Spring 2011 (Volume 39, issue 1 (http://www.federallegalpublications.com/journal-of-psychiatry-law/201110/jpl-2011-39-1-journal-of-psychiatry-law-volume-39-number-1-spring-2)) issues of The Journal of Psychiatry & Law are devoted entirely to FASD-related issues, ranging from intervention approaches, to addressing FASD in the criminal justice system, to FASD as an adoption disclosure issue. A full listing of the articles is contained at the Volume links above. Note: There is a cost for each full issue.
Research Search Engines
Both the SAMHSA FASD Center for Excellence and NOFAS offer free online search engines that can be used to access FASD-related literature by author, title, keywords, or topic area.

## Support Networks for Individuals with an FASD and Their Families

Birth Mothers Network http://www.nofas.org/join-the-circle-of-hope/
The Birth Mothers Network, also known as the Circle of Hope, was founded through NOFAS in 2004. It is a network of women who have consumed alcohol during pregnancy and may have a child or children with an FASD. Members are lovingly referred to as “Warrior Moms” because of their incredible strengths. Many of the women are in recovery from alcoholism, or alcohol and drug addiction. However, the network also includes women without the disease of addiction, but who drank alcohol during pregnancy. The women of the Birth Mothers Network serve as mentors to one another, help each other cope with the challenges of parenting a child with an FASD, and provide caring, non-judgmental support to members who are in recovery.
Living With FASD http://www.nofas.org/living
The Living With FASD page is provided by NOFAS, and contains links to financial assistance programs such as Supplemental Security Income (SSI) and Social Security Disability Insurance (SSDI) (both can be contacted at 1-800-772-1213), and [underlined: Medicaid], as well as family and mother support programs such as (Women, Infants and Children (http://www.fns.usda.gov/wic)) (WIC).
Additional Support Sites
In addition to research and general information, each of the following sites provides access to other members of the FASD community, as well as parenting guidance, personal stories from others who are coping with FASD, and guides to services.
- The FAS Community Resource Center
http://www.come-over.to/FASCRC/
- FASlink
http://www.faslink.org/
- One-Stop Centers
http://www.careeronestop.org/
One-Stop Centers are Internet job sites that can provide links to your state Department of Labor and Workforce Development, the local division for vocational rehabilitation services, and/or specific state initiatives for development of customized employment for people with disabilities.