# Selected Screening Instruments for Identifying Alcohol Use Among Women

[NOTE: Part 3 of this TIP, the online Literature Review, contains a full discussion of these and other alcohol screening instruments for use with women.]

T-ACE

TWEAK

The CRAFFT Screening Interview

AUDIT-C