# Bibliography

[NOTE: Part 3 of this TIP, the online Literature Review, contains its own separate reference list.]

Aase JM, Jones KL, Clarren SK. Do we need the term FAE?. Pediatrics. 1995;95(3):428-430. [pmid: 7862486].
Abel EL, Sokol RJ. Incidence of fetal alcohol syndrome and economic impact of FAS-related anomalies: Drug alcohol syndrome and economic impact of FAS-related anomalies. Drug and Alcohol Dependency. 1987;19(1):51-70.
Abel EL, Sokol RJ. A revised conservative estimate of the incidence of FAS and its economic impact. Alcoholism: Clinical and Experimental Research. 1991;15(3):514-524.
Addiction Technology Transfer Center. 2004. The change book: A blueprint for technology transfer. 2nd ed. Kansas City, MO. Addiction Technology Transfer Center.
Adubato SA, Cohen DE. 2011. Prenatal alcohol use and Fetal Alcohol Spectrum Disorders: Diagnosis, assessment and new directions in research and multimodal treatment. Oak Park, IL. Bentham Science Publishers.
Amendah DD, Grosse SD, Bertrand J. Medical expenditures of children in the United States with Fetal Alcohol Syndrome. Neurotoxicology and Teratology. 2010;33(2):322-324. [pmid: 21073947].
American Psychiatric Association. 2000. Diagnostic and statistical manual of mental disorders, fourth edition, text revision. Washington DC. American Psychiatric Association.
Anderson JE, Ebrahim S, Floyd L, Atrash H. Prevalence of risk factors for adverse pregnancy outcomes during pregnancy and the preconception period—United States, 2002-2004. Maternal & Child Health Journal. 2006;10(1):101-106.
Andrew G. Diagnosis of FASD: An overview. Riley EP, Clarren S, Weinberg J, Jonsson E, editors. Fetal Alcohol Spectrum Disorder: Management and policy perspectives of FASD. 2011:127-148. Weinheim, Germany. Wiley-Blackwell.
Anthony EK, Austin MJ, Cormier DR. Early detection of prenatal substance exposure and the role of child welfare. Children and Youth Services Review. 2010;32:6-12.
Astley SJ. Fetal Alcohol Syndrome prevention in Washington State: Evidence of success. Paediatric and Perinatal Epidemiology. 2004;18:341-355. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
Astley SJ. 2004. Diagnostic guide for Fetal Alcohol Spectrum Disorders: The 4-Digit Diagnostic Code. Third Edition. Seattle, WA. University of Washington. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
Astley SJ. Profile of the first 1,400 patients receiving diagnostic evaluations for Fetal Alcohol Spectrum Disorder at the Washington State Fetal Alcohol Syndrome Diagnostic and Prevention Network. Canadian Journal of Clinical Pharmacology. 2010;17(1):e132-64. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 20335648].
Astley SJ. Diagnosing Fetal Alcohol Spectrum Disorders (FASD). Adubato SA, Cohen DE, editors. Prenatal alcohol use and Fetal Alcohol Spectrum Disorders: Diagnosis, assessment and new directions in research and multimodal treatment. 2011:3-29. Oak Park, IL. Bentham Science Publishers. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
Astley SJ, Aylward EH, Olson HC, Kerns K, Brooks A, Coggins T, Coggins E, Richards T. Functional magnetic resonance imaging outcomes from a comprehensive magnetic resonance study of children with Fetal Alcohol Spectrum Disorders. Journal of Neurodevelopmental Disorders. 2009;1(1):61-80. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 21547622].
Astley SJ, Bailey D, Talbot C, Clarren SK. FAS primary prevention through FAS diagnosis: Part I. Identification of high-risk birth mothers through diagnosis of their children. Alcohol & Alcoholism. 2000;35(5):499-508. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 11022025].
Astley SJ, Olson HC, Kerns K, Brooks A, Aylward E, Coggins TE, Richards T. Neuropsychological and behavioral outcomes from a comprehensive magnetic resonance study of children with fetal alcohol spectrum disorders. Canadian Journal of Clinical Pharmacology. 2009;16(1):e178-201. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 19329824].
Astley SJ, Bailey D, Talbot C, Clarren SK. Fetal Alcohol Syndrome (FAS) primary prevention through FAS diagnosis: II. A comprehensive profile of 80 birth mothers of children with FAS. Alcohol & Alcoholism. 2000;35(5):509-519. January 13, 2014. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 11022026].
Astley SJ, Stachowiak J, Clarren SK, Clausen C. Application of the Fetal Alcohol Syndrome facial photographic screening tool in a foster care population. The Journal of Pediatrics. 2002;141(5):712-717. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 12410204].
Baxter SL. Adapting talk therapy for individuals with FAS/E. Kleinfeld J, Morse B, Wescott S, editors. Fantastic Antone Grows Up. 2000:169-191. Fairbanks. University of Alaska Press.
Bays J. The care of alcohol- and drug-affected infants. Pediatric Annals. 1992;21:485-495. [pmid: 1508575].
Bertrand J. Interventions for children with Fetal Alcohol Spectrum Disorders (FASDs): Overview of findings for five innovative research projects. Research in Developmental Disabilities. 2009;30(5):986-1006. [pmid: 19327965].
Bertrand J, Floyd RL, Weber MK, O'Connor M, Riley EP, Johnson KA, Cohen DE. 2004. National Task Force on Fetal Alcohol Syndrome and Fetal Alcohol Effect Fetal Alcohol Syndrome: Guidelines for referral and diagnosis. Atlanta, GA. Centers for Disease Control and Prevention.
Bishop S, Gahagan S, Lord C. Re-examining the core features of Autism: A comparison of Autism Spectrum Disorder and Fetal Alcohol Spectrum Disorder. Journal of Child Psychology & Psychiatry. 2007;48(11):1111-1121. [pmid: 17995487].
Blacher J, Baker BL. Positive impact of intellectual disability on families. American Journal on Mental Retardation. 2007;112(5):330-348. [pmid: 17676958].
Bobo JK, Klepinger DH, Dong FB. Identifying social drinkers like to consume alcohol during pregnancy: Findings from a prospective cohort study. Psychological Reports. 2007;101:857-870. [pmid: 18232442].
Bonthius DJ, West JR. Blood alcohol concentration and microencephaly: A dose-response study in the neonatal rat. Teratology. 1988;37(3):223-231. [pmid: 3368876].
Boyce MC. A better future for baby: Stemming the tide of Fetal Alcohol Syndrome. The Journal of Family Practice. 2010;59(6):337-345. [pmid: 20544066].
Bradley KA, Bush KR, Epler AJ, Dobie DJ, Davis TM, Sporleder JL, Kivlahan DR. Two brief alcohol-screening tests From the Alcohol Use Disorders Identification Test (AUDIT): Validation in a female Veterans Affairs patient population. Archives of Internal Medicine. 2003;163(7):821-829. [pmid: 12695273].
Bradley KA, Bush KR, McDonell MB, Malone T, Fihn SD. Screening for problem drinking: Comparison of CAGE and AUDIT. Ambulatory Care Quality Improvement Project (ACQUIP). Alcohol Use Disorders Identification Test. Journal of General Internal Medicine. 1998;13(6):379-388.
Bradley KA, DeBenedetti AF, Volk RJ, Williams EC, Frank D, Kivlahan DR. AUDIT-C as a brief screen for alcohol misuse in primary care. Alcoholism: Clinical and Experimental Research. 2007;31(7):1-10.
Brown NN, Gudjonsson I, Connor P. Suggestibility and Fetal Alcohol Spectrum Disorders: I'll tell you anything you want to hear. Journal of Psychiatry & Law. 2011;39:39-71.
Burden MJ, Jacobson SW, Sokol RJ, Jacobson JL. Effects of prenatal alcohol exposure on attention and working memory at 7.5 years of age. Alcoholism: Clinical and Experimental Research. 2005;29(3):443-452.
Burke KD. Substance-expose newborns: Hospital and child protection responses. Children and Youth Services Review. 2007;29(12):1503-1519.
Burke BL, Arkowitz H, Menchola M. The efficacy of motivational interviewing: a meta-analysis of controlled clinical trials. Journal of Consulting and Clinical Psychology. 2003;71:843-861. [pmid: 14516234].
Bush K, Kivlahan DR, McDonell MB, Fihn SD, Bradley KA. The AUDIT alcohol consumption questions (AUDIT-C): An effective brief screening test for problem drinking. Archives of Internal Medicine. 1998;158(16):1789-195. [pmid: 9738608].
Caetano R. 2010. Epidemiology of drinking among women of childbearing age and approaches to FAS prevention. Presentation to the Building FASD State Systems Conference. Nashville, TN. May 6, 2010. Center for Substance Abuse Treatment Prevention.
Center for Behavioral Health Quality and Statistics. 2010. Results from the 2009 National Survey on Drug Use and Health (NSDUH): Mental Health Findings. Rockville, MD. Substance Abuse and Mental Health Services Administration. September 1, 2013. http://www.samhsa.gov/data/NSDUH/2k9NSDUH/MH/2K9MHResults.htm.
Center for Behavioral Health Quality and Statistics. 2013. Treatment Episode Data Set (TEDS): 2001-2011. National Admissions to Substance Abuse Treatment Services. Rockville, MD. Substance Abuse and Mental Health Services Administration. September 1, 2013. http://www.samhsa.gov/data/2k13/TEDS2011/TEDS2011N.pdf.
Centers for Disease Control and Prevention. Alcohol use among women of childbearing age—United States, 1991–1999. Morbidity and Mortality Weekly Report: Surveillance Summaries. 2002;51:273-276.
Centers for Disease Control and Prevention. 2010. Autism Spectrum Disorders. September 30, 2011. http://www.cdc.gov/ncbddd/autism/data.html.
Center for Substance Abuse Treatment. 1999. Enhancing motivation for change in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 35. DHHS Publication No. (SMA) 01-3519. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Implementing change in substance abuse treatment programs. Technical Assistance Publication Series 31. HHS Publication No. (SMA) 09-4377. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2008. Managing depressive symptoms in substance abuse clients during early recovery. Treatment Improvement Protocol (TIP) Series 48. DHHS Publication No. (SMA) 08-4353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Chang G. Alcohol screening instruments for pregnant women. Alcohol Research & Health. 2001;25(3):204-209. [pmid: 11810959].
Chang G, McNamara TK, Orav EJ, Koby D, Lavigne A, Ludman B, Wilkins-Haug L. Brief intervention for prenatal alcohol use: A randomized trial. Obstetrics & Gynecology. 2005;105(5-1):991-998. [pmid: 15863535].
Chang G, Wilkins-Haug L, Berman S, Goetz MA. The TWEAK: Application in a prenatal setting. Journal of Studies on Alcohol. 1999;60(3):306-309. [pmid: 10371256].
Chapman S, Borland R, Scollo M, Brownson RC, Dominello A, Woodward S. The impact of smoke-free workplaces on declining cigarette consumption in Australia and the United States. American Journal of Public Health. 1999;89(7):1018-1023. [pmid: 10394309].
Chavez GF, Cordero JF, Becerra JE. Leading major congenital malformations among minority groups in the United States, 1981-1986. Morbidity and Mortality Weekly Report. 1988;37(3):17-24. [pmid: 3122005].
Cherpitel CJ, Korcha RA, Moskalewicz J, Swiatkiewicz G, Ye Y, Bond J. Screening, Brief Intervention, and Referral to Treatment (SBIRT): 12-Month outcomes of a randomized controlled clinical trial in a Polish emergency department. Alcoholism: Clinical & Experimental Research. 2010;34(11):1922-1928.
Chiodo LM, Janisse J, Delaney-Black V, Sokol RJ, Hannigan J. A metric of maternal prenatal risk drinking predicts neurobehavioral outcomes in preschool children. Alcoholism: Clinical and Experimental Research. 2009;33(4):634-644.
Chudley AE, Conry J, Cook JL, Loock C, Rosales T, LeBlanc N. Fetal Alcohol Spectrum Disorder: Canadian guidelines for diagnosis. Canadian Medical Association Journal. 2005;172(5):S1-S21. [pmid: 15738468].
Clark E, Lutke J, Minnes P, Quellette-Kuntz H. Secondary disabilities among adults with Fetal Alcohol Spectrum Disorder in British Columbia. Journal of FAS International. 2004;2(e13):1-12.
Clarren SK, Astley SJ. The development of the Fetal Alcohol Syndrome Diagnostic and Prevention Network in Washington State. Streissguth A, Kanter J, editors. The Challenge of Fetal Alcohol Syndrome: Overcoming Secondary Disabilities. 1997:40-51. Seattle, WA. University of Washington Press. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
Clarren SK, Astley SJ, Gunderson VM, Spellman D. Cognitive and behavioral deficits in nonhuman primates associated with very early embryonic binge exposures to ethanol. The Journal of Pediatrics. 1992;121(5):789-796. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 1432435].
Clarren SK, Carmichael-Olson H, Clarren SGB, Astley SJ. A child with Fetal Alcohol Syndrome. Guralnick MJ, editor. Handbook of Clinical Assessment for Young Children with Developmental Disabilities. 2000:307-326. Baltimore, MD. Paul H. Brookes. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
Clarren SK, Smith DW. The Fetal Alcohol Syndrome. New England Journal of Medicine. 1978;298(19):1063-1067. [pmid: 347295].
Coles CD. Intervening with children with FAS and ARND: Where do we start. Centers for Disease Control and Prevention, editor. Intervening with Children Affected by Prenatal Alcohol Exposure: Proceedings of a Special Focus Session of the Interagency Coordinating Committee on Fetal Alcohol Syndrome September 10-11, 1998. 1999:103-115. Chevy Chase, MD. National Institute of Alcohol Abuse and Alcoholism.
Coles CD, Kable JA, Taddeo E. Math performance and behavioral problems in children affected by prenatal alcohol exposure: Intervention and follow-up. Journal of Developmental Disabilities. 2009;28(5):518-530.
Coe J, Sidders J, Riley K, Waltermire J, Hagerman R. A survey of medication responses in children and adolescents with Fetal Alcohol Syndrome. Mental Health Aspects of Developmental Disabilities. 2001;4(4):148-155.
Committee on Ethics. 2008. ACOG Committee Opinion Number 422: At-Risk Drinking and Illicit Drug Use: Ethical Issues in Obstetric and Gynecologic Practice (December 2008). Washington DC. American College of Obstetricians and Gynecologists.
Connor PD, Streissguth AP. Effects of prenatal exposure to alcohol across the lifespan. Alcohol Health and Research World. 1996;20:170-174.
De Bellis M, Thomas L. Biologic findings of post-traumatic stress disorder and child maltreatment. Current Psychiatry Repots. 2003;5:108-117.
De Vos G. 2003. Women, justice and Fetal Alcohol Syndrome & Fetal Alcohol Effects: Defining the needs of the Elizabeth Fry Society to enhance work with women affected by FAS/E. Manitoba, AB. University of Manitoba.
Denys K, Rasmussen C, Henneveld D. The effectiveness of a community-based intervention for parents with FASD. Community Mental Health Journal. 2011;47(2):209-219. [pmid: 21526509].
DiClemente CC. Motivational interviewing and stages of change. Miller WR, Rollnick S, editors. Motivational Interviewing: Preparing People to Change Addictive Behaviors. 1991:191-206. New York. Guilford.
Division of Women's Health Issues. 2006. Drinking and reproductive health: A Fetal Alcohol Spectrum Disorders prevention tool kit. Washington DC. American College of Obstetricians and Gynecologists.
Dum M, Sobell LC, Sobell MB, Heinecke N, Voluse A, Johnson K. A Quick Drinking Screen for identifying women at risk for an alcohol-exposed pregnancy. Addictive Behaviors. 2009;34:714-716. [pmid: 19406583].
Elder RW, Lawrence B, Ferguson A, Naimi TS, Brewer RD, Chattopadhyay SK, Task Force on Community Preventive Services. The effectiveness of tax policy interventions for reducing excessive alcohol consumption and related harms. American Journal of Preventive Medicine. 2010;38(2):217-229. [pmid: 20117579].
Ethen MK, Ramadhani TA, Scheuerle AE, Canfield MA, Wyszynski DF, Druschel CM, National Birth Defects Prevention Study. Alcohol consumption by women before and during pregnancy. Maternal and Child Health Journal. 2009;13(2):274-285. [pmid: 18317893].
Fabian E, Ethridge G, Beveridge S. Differences in perceptions of career barriers and supports for people with disabilities by demographic background and case status factor. Journal of Rehabilitation. 2009;75(1):41-49.
Fast DK, Conry J, Loock C. Identifying Fetal Alcohol Syndrome among youth in the criminal justice system. Journal of Developmental and Behavioral Pediatrics. 1999;20(5):370-372. [pmid: 10533996].
Feldman HS, Jones KL, Lindsay S, Slymen D, Klonoff-Cohen H, Kao K, Chambers C. Prenatal alcohol exposure patterns and alcohol-related birth defects and growth deficiencies: A prospective study. Alcoholism: Clinical and Experimental Research. 2012;36(4):670-676.
Finer L, Henshaw S. 2006. Estimates of abortion incidence 2001-2003. New York. Guttmacher Institute.
Fixsen DL, Naoom SF, Blase KA, Friedman RM, Wallace F. 2005. Implementation research: A synthesis of the literature. Tampa, FL. University of South Florida, Louis de la Parte Florida Mental Health Institute, The National Implementation Research Network. FMHI Publication #231.
Fleming MF, Barry KL, Manwell LB, Johnson K, London R. Brief physician advice for problem alcohol drinkers: A randomized controlled trial in community-based primary care practices. The Journal of the American Medical Association. 1997;277(13):1039-1045. [pmid: 9091691].
Floyd RL, Sobell M, Velasquez MM, Ingersoll K, Nettleman M, Sobell L, Project CHOICES Efficacy Study Group. Preventing alcohol-exposed pregnancies: A randomized controlled trial. American Journal of Preventive Medicine. 2007;32(1):1-10. [pmid: 17218187].
Floyd RL, Weber MK, Denny C, O'Connor MJ. Prevention of Fetal Alcohol Spectrum Disorders. Developmental Disabilities Research Reviews. 2009;15:193-199. [pmid: 19731392].
Frank D, Debenedetti AF, Volk RJ, Williams EC, Kivlahan DR, Bradley KA. Effectiveness of the AUDIT-C as a screening test for alcohol misuse in three racial/ethnic groups. Journal of General Internal Medicine. 2008;23(6):781-787. [pmid: 18421511].
Freunscht I, Feldmann R. Young adults with Fetal Alcohol Syndrome (FAS): social, emotional and occupational development. Klinische Pädiatrie. 2011;223(1):33-7. [pmid: 20677126].
Fryer SL, McGee CL, Matt GE, Riley EP, Mattson SN. Evaluation of psychopathological conditions in children with heavy prenatal alcohol exposure. Pediatrics. 2007;119(3):e733-e741. [pmid: 17332190].
Gobelet C, Luthi F, Al-Khodairy A, Chamberlain M. Vocational rehabilitation: A multidisciplinary intervention. Disability and Rehabilitation. 2007;29(17):1405-1410. [pmid: 17729086].
Goodacre K, Mercer ED. 1965. Guide to the Middlesex Sessions Records, 1549-1889. Middlesex, England. Greater London Record Office.
Goodlett CR. Fetal Alcohol Spectrum Disorders: New perspectives on diagnosis and intervention. Alcohol. 2010;44:579-582. [pmid: 21112470].
Grant TM. Preventing FASD: The Parent-Child Assistance Program (PCAP) intervention with high-risk mothers. Riley EP, Clarren S, Weinberg J, Jonsson E, editors. Fetal Alcohol Spectrum Disorder: Management and policy perspectives of FASD. 2011:193-206. Weinheim, Germany. Wiley-Blackwell.
Grant T, Ernst C, Streissguth A, Porter J. An advocacy program for mothers with FAS/FAE. Streissguth A, Kanter J, editors. The Challenge of Fetal Alcohol Syndrome: Overcoming Secondary Disabilities. 1997:102-112. Seattle. University of Washington Press.
Grant TM, Ernst CC, Streissguth A, Stark K. Preventing alcohol and drug exposed births in Washington state: Intervention findings from three Parent-Child Assistance Program sites. The American Journal of Drug and Alcohol Abuse. 2005;31:471-490.
Grant T, Huggins J, Connor P, Pedersen J, Whitney N, Streissguth A. A pilot community intervention for young women with Fetal Alcohol Spectrum Disorders. Community Mental Health Journal. 2004;40(6):499-511. [pmid: 15672689].
Green CR, Mihic AM, Armstrong IT, Nikkel SM, Stade BC, Rasmussen C, Reynolds JN. Executive function deficits in children with Fetal Alcohol Spectrum Disorders (FASD) measured using the Cambridge Neuropsychological Tests Automated Batter (CANTAB). Journal of Child Psychology & Psychiatry. 2009;50(6):688-697. [pmid: 19175817].
Green CR, Mihic AM, Brien DC, Armstrong IT, Nikkel SM, Stade BC, Reynolds JN. Oculomotor control in children with Fetal Alcohol Spectrum Disorders assessed using a mobile eye-tracking laboratory. European Journal of Neuroscience. 2009;29:1302-1309. [pmid: 19302166].
Greenbaum RL, Stevens SA, Nash K, Koren G, Rovet J. Social cognitive and emotion processing abilities of children with Fetal Alcohol Spectrum Disorders: A comparison with Attention Deficit Hyperactivity Disorder. Alcoholism: Clinical & Experimental Research. 2009;33(10):1656-1670.
Greenspan S. Foolish action in adults with intellectual disabilities: The forgotten problem of risk unawareness. Glidden LM, editor. International review of research in mental retardation. 2009;36:147-194. New York, NY. Elsevier.
Guerri C, Bazinet A, Riley EP. Foetal Alcohol Spectrum Disorders and alterations in brain and behavior. Alcohol and Alcoholism. 2009;44(2):108-114. December 2, 2011. http://alcalc.oxfordjournals.org/content/44/2/108.long. [pmid: 19147799].
Hankin JR, Firestone IJ, Sloan JJ, Ager JW, Sokol RJ, Martier SS. Heeding the alcoholic beverage warning label during pregnancy: Multiparae versus nulliparae. Journal of Studies on Alcohol and Drugs. 1996;57(2):171-177.
Harden BJ. Safety and stability for foster children: A developmental perspective. Future of Children. 2004;14(1):30-47. [pmid: 15072017].
Harwood HJ, Napolitano DM. Economic implications of the Fetal Alcohol Syndrome. Alcohol Health & Research World. 1985;10(1):38-43. 74. 75.
Henry J, Sloane M, Black-Pond C. Neurobiology and neurodevelopmental impact of childhood traumatic stress and prenatal alcohol exposure. Language, Speech and Hearing Services in Schools. 2007;38(2):99-108.
Hicks M, Tough S. The importance of complete abstinence from alcohol before and during pregnancy: Enough evidence for justification?. Expert Review of Obstetrics & Gynecology. 2009;4(4):401-414.
Higgins-Biddle J, Hungerford D, Cates-Wessel K. 2009. Screening and brief interventions (SBI) for unhealthy alcohol use: A step-by-step implementation guide for trauma centers. Atlanta. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control.
Hoyme HE, May PA, Kalberg WO. A practical clinical approach to the diagnosis of Fetal Alcohol Spectrum Disorders: Clarification of the 1996 Institute of Medicine criteria. Pediatrics. 2005;115:39-47. [pmid: 15629980].
Hser Y, Grella C, Evans E, Huang Y. Utilization and outcomes of mental health services among patients in drug treatment. Journal of Addictive Diseases. 2006;25(1):73-85. [pmid: 16597575].
Huggins JE, Grant T, O'Malley K, Streissguth A. Suicide attempts among adults with Fetal Alcohol Spectrum Disorders: Clinical considerations. Mental Health Aspects of Developmental Disabilities. 2008;11(2):33-42.
Institute of Health Economics. 2009. Fetal Alcohol Spectrum Disorders (FASD): Across the lifespan. Proceedings from a Consensus Development Conference. Alberta, CA. Institute of Health Economics.
Interagency Coordinating Committee on FASD. 2011. Consensus Statement: Recognizing Alcohol-Related Neurodevelopmental Disorder (ARND) in Primary Health Care of Children. Proceedings from a Consensus Development Conference. Rockville, MD. Interagency Coordinating Committee on FASD.
Jirikowic T, Gelo J, Astley J. Children and youth with Fetal Alcohol Spectrum Disorders: Summary of intervention recommendations after clinical diagnosis. Intellectual and Developmental Disabilities. 2010;48(5):330-344. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 20973697].
Jirikowic T, Kartin D, Olson HC. Children with Fetal Alcohol Spectrum Disorders: A descriptive profile of adaptive function. Canadian Journal of Occupational Therapy. 2008;75(4):236-246.
Jones KL, Smith DW. Recognition of fetal alcohol syndrome in early infancy. Lancet. 1973;2:999-1001. [pmid: 4127281].
Jones K, Smith DW, Ulleland C, Streissguth A. Pattern of malformation in offspring of chronic alcoholic mothers. Lancet. 1973;1:1267-1271. [pmid: 4126070].
Kalberg WO, Provost B, Tollison SJ, Tabachnick BG, Robinson LK, Hoyme HE, May PA. Comparison of motor delays in young children with Fetal Alcohol Syndrome to those with prenatal alcohol exposure and with no prenatal alcohol exposure. Alcoholism: Clinical and Experimental Research. 2006;30(12):2037-2045.
Kellerman T. 2005. Recommended assessment tools for children and adults with confirmed or suspected FASD.
Kellerman T. 2003. External brain. October 6, 2011. http://come-over.to/FAS/externalbrain.htm.
Ker K, Chinnock P. 2008. Interventions in the alcohol server setting for preventing injuries. Cochrane Database of Systematic Reviews, Issue 3. article number CD005244.
Knight JR, Sherritt L, Shrier LA, Harris SK, Chang G. Validity of the CRAFFT substance abuse screening test among adolescent clinic patients. Archives of Pediatrics & Adolescent Medicine. 2002;156(6):607-614. [pmid: 12038895].
Knight JR, Shrier LA, Bravender TD, Farrell M, VanderBilt J, Shaffer HJ. A new brief screen for adolescent substance abuse. Archives of Pediatrics & Adolescent Medicine. 1999;153(6):591-596. [pmid: 10357299].
Kodituwakku PW. Defining the behavioral phenotype in children with Fetal Alcohol Spectrum Disorders: A review. Neuroscience and Biobehavioral Reviews. 2007;31:192-201. [pmid: 16930704].
Kodituwakku PW, Handmaker NS, Cutler SK, Weathersby EK, Handmaker SD. Specific impairments in self-regulation in children exposed to alcohol prenatally. Alcoholism: Clinical and Experimental Research. 1995;19:1558-1564.
Kodituwakku P, Kalberg M, May P. The effects of prenatal alcohol exposure on executive functioning. Alcohol Res Health. 2001;25:192-198. [pmid: 11810957].
Kodituwakku PW, Kodituwakku EL. From research to practice: An integrative framework for the development of interventions for children with Fetal Alcohol Spectrum Disorders. Neuropsychology Review. 2011;21(2):204-223. [pmid: 21544706].
Kutner M. 2006. Health literacy of America's adults. Presentation to the Meeting of the Minds II Symposium. Sacramento, CA. November 30, 2006. American Institutes of Research.
Kvigne VL, Leonardson GR, Borzelleca J, Brock E, Neff-Smith M, Welty TK. Characteristics of mothers who have children with Fetal Alcohol Syndrome or some characteristics of Fetal Alcohol Syndrome. The Journal of the American Board of Family Medicine. 2003;16:293-303.
Lee KT, Mattson SN, Riley EP. Classifying children with heavy prenatal alcohol exposure using measures of attention. Journal of the International Neuropsychological Society. 2004;10:271-277. [pmid: 15012847].
Lehman WEK, Greener JM, Simpson DD. Assessing organizational readiness for change. Journal of Substance Abuse Treatment. 2002;22(4):197-209. [pmid: 12072164].
Lemoine P, Harousseau H, Borteyni J, Menuet J. Les enfants des parents alcoholiques: anomolies observees a propos de 127 cas. The children of alcoholic parents: anomalies observed in 127 cases. Quest Medical. 1968;25:476-482.
Leon L, Matthews L. Self-esteem theories: Possible explanations for poor interview performance for people experiencing unemployment. Journal of Rehabilitation. 2010;76(1):41-50.
Leonardson GR, Loudenburg R, Struck J. Factors predictive of alcohol use during pregnancy in three rural states. Behavioral and Brain Functions. 2007;3:8. June 13, 2011. http://www.behavioralandbrainfunctions.com/content/3/1/8. [pmid: 17291346].
Liechty JM. Health literacy: Critical opportunities for social work leadership in health care and research. Health & Social Work. 2011;36(2):99-107. [pmid: 21661299].
Lupton C, Burd L, Harwood R. Cost of fetal alcohol spectrum disorders. American Journal of Medical Genetics. 2004;127C(671):42-50. [pmid: 15095471].
MacKinnon DP, Nohre L, Pentz MA, Stacy AW. The alcohol warning and adolescents: 5-year effects. American Journal of Public Health. 2000;90(10):1589-1594. [pmid: 11029993].
Madras BK, Compton WM, Avula D, Stegbauer T, Stein JB, Clark HW. Screening, brief interventions, referral to treatment (SBIRT) for illicit drug and alcohol use at multiple healthcare sites: Comparison at intake and 6 months later. Drug and Alcohol Dependence. 2009;99(1-3):280-295. [pmid: 18929451].
Malbin D. 1993. Fetal Alcohol Syndrome Fetal Alcohol Effects: Strategies for professionals. Center City, MN. Hazelden Educational Materials.
Manwell LB, Fleming MF, Mundt MP, Stauffacher EA, Barry KL. Treatment of problem alcohol use in women of childbearing age: Results of a brief intervention trial. Alcoholism: Clinical and Experimental Research. 2002;24:1517-1524.
Marlatt GA, Witkiewicz K. Harm reduction approaches to alcohol use: Health promotion, prevention, and treatment. Addictive Behaviors. 2002;27:867-886. [pmid: 12369473].
Mattson SN, Crocker N, Nguyen TT. Fetal Alcohol Spectrum Disorders: Neuropsychological and behavioral features. Neuropsychology Review. 2011;21:81-101. [pmid: 21503685].
Mattson SN, Roesch SC, Fagerlund A, Autti-Ramo I, Jones KL, May PA, Adnams CM, Konovalova V, Riley EP, the Collaborative Initiative on Fetal Alcohol Spectrum Disorders (CIFASD). Toward a neurobehavioral profile of Fetal Alcohol Spectrum Disorders. Alcoholism: Clinical and Experimental Research. 2010;34(9):1640-1650.
Mattson SN, Schoenfeld AM, Riley EP. Teratogenic effects of alcohol on brain and behavior. Alcohol Research and Health. 2001;25(3):185-191. [pmid: 11810956].
May PA, Gossage JP, Brooke LE, Snell CL, Marais A, Hendricks LS, Viljoen DL. Maternal risk factors for Fetal Alcohol Syndrome in the Western Cape Province of South Africa: A population-based study. American Journal of Public Health. 2005;95(7):1190-1199. [pmid: 15933241].
May PA, Gossage JP, Kalberg WO, Robinson LK, Buckley D, Manning M, Hoyme HE. Prevalence and epidemiologic characteristics of FASD from various research methods with an emphasis on recent in-school studies. Developmental Disabilities Research Reviews. 2009;15(3):176-192. [pmid: 19731384].
McGee C, Fryer S, Bjorquist O, Mattson S, Riley E. Deficits in social problem solving in adolescents with prenatal exposure to alcohol. The American Journal of Drug and Alcohol Abuse. 2008;34:423-431. [pmid: 18584572].
McGinty K, Worthington R, Dennison W. Patient and family advocacy: Working with individuals with comorbid mental illness and developmental disabilities and their families. Psychiatric Quarterly. 2008;79(3):193-203. [pmid: 18726692].
Merrick J, Merrick E, Morad M, Kandel I. Fetal Alcohol Syndrome and its long-term effects. Minerva Pediatrica. 2006;58(3):211-218. [pmid: 16832326].
Migliore A, Grossi T, Mank D, Rogan P. Integrated employment or sheltered workshops: Preference of adults with intellectual disabilities, their families, and staff. Journal of. Vocational Rehabilitation. 2007;26:5-19.
Migliore A, Grossi T, Mank D, Rogan P. Why do adults with intellectual disabilities work in sheltered workshops?. Journal of Vocational Rehabilitation. 2008;28:29-40.
Miller WR, Rollnick S. 2002. Motivational interviewing: Preparing people for change. 2nd ed. New York, NY. Guildford Press.
Miller WR, Sanchez VC. Motivating young adults for treatment and lifestyle change. Howard G, editor. Issues in Alcohol Use and Misuse By Young Adults. 1994:55-82. Notre Dame, IN. University of Notre Dame Press.
Millon T, Millon C, Davis R. 1993. Millon Adolescent Clinical Inventory & (MACI) Manual. Minneapolis. NCS Assessments & NCS Pearson, Inc.
Moore TE, Green M. Fetal Alcohol Spectrum Disorder (FASD): A need for closer examination by the criminal justice system. Criminal Reports. 2004;19(1):99-108.
Moore ES, Ward RE, Rogers JL, Mattson SN, Autti-Rämö I, Fagerlund A, the CIFASD. Identification of prenatal alcohol exposure using combined 3D facial imaging and neurobehavioral data. Presented at the Research Society on Alcoholism meeting. San Diego. June 2009. Alcoholism: Clinical and Experimental Research. Supplement S1. 2009;33:39A.
Morleo M, Woolfall K, Dedman D, Mukherjee R, Bellis MA, Cook PA. Under-reporting of Foetal Alcohol Spectrum Disorders: An analysis of hospital episode statistics. BMC Pediatrics. 2011;11:14. [pmid: 21303524].
Morse BA, Hutchins E. Reducing complications from alcohol use during pregnancy through screening. Journal of the American Medical Women's Association. 2000;55(4):225-227. 240.
Moseley L, Gradisar M. Evaluation of a school-based intervention for adolescent sleep problems. Sleep. 2009;32(3):334-341. [pmid: 19294953].
Murphy N, Elias E. Sexuality of children and adolescents with developmental disabilities. Pediatrics. 2006;118(1):398-403. [pmid: 16818589].
Nanson JL, Hiscock M. Attention deficits in children exposed to alcohol prenatally. Alcoholism: Clinical and Experimental Research. 1990;14:656-661.
National Center for Birth Defects and Developmental Disabilities. 2005. Fetal Alcohol Syndrome: Guidelines for referral and diagnosis. Washington, DC. Centers for Disease Control and Prevention.
National Highway Traffic Safety Administration. 2007. Fatality Analysis Reporting System (FARS). Washington DC. U.S. Department of Transportation.
National Institute on Alcohol Abuse and Alcoholism. 2000. 10th special report to the US Congress on alcohol and health. Washington, DC. U.S. Department of Health and Human Services.
National Institute on Alcohol Abuse and Alcoholism. NIAAA Council Approves Definition of Binge Drinking. NIAAA Newsletter. Winter. 2004;2004(3).
National Institute on Alcohol Abuse and Alcoholism. Brief Interventions. NIAAA Alcohol Alert. July. 2005. 2005;(66).
National Institute on Alcohol Abuse and Alcoholism. 2007. Helping patients who drink too much: A clinician's guide. Washington, DC. U.S. Department of Health and Human Services.
Neely-Barnes S, Graff JC, Marcenko M, Weber L. Family decision-making: Benefits to persons with developmental disabilities and their family members. Journal of Intellectual and Developmental Disability. 2008;46(3):93-105.
Noland JS, Singer LT, Arendt RE, Minnes S, Short EJ, Bearer CF. Executive functioning in preschool-age children prenatally exposed to alcohol, cocaine, and marijuana. Alcoholism: Clinical and Experimental Research. 2003;27(4):647-656.
O'Connor MJ, Shah B, Whaley S, Cronin P, Gunderson B, Graham J. Psychiatric illness in a clinical sample of children with prenatal alcohol exposure. The American Journal of Drug and Alcohol Abuse. 2002;28(4):743-754. [pmid: 12492268].
O'Connor MJ, Whaley SE. Brief intervention for alcohol use by pregnant women. American Journal of Public Health. 2007;97(2):252-258. [pmid: 17194863].
Office of Applied Studies. 2006. Treatment Episode Data Set (TEDS), 2006. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Office of Applied Studies. 2009. The NSDUH Report: Substance Use Among Women During Pregnancy and Following Childbirth (May 21, 2009). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Office of Applied Studies. 2009. National Survey on Drug Use and Health (NSDUH), 2002-2009. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Office of Applied Studies. 2011. Results from the 2010 National Survey on Drug Use and Health: Summary of National Findings. NSDUH Series H-41. HHS Publication No. (SMA) 11-4658. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Office of the Surgeon General. 2005. US Surgeon General releases advisory on alcohol use in pregnancy. Rockville, MD. U.S. Department of Health and Human Services.
O'Leary C. 2005. Fetal Alcohol Syndrome. Developmental Disability Steering Group, editor. Management Guidelines: Developmental Disability. Melbourne. Therapeutic Guidelines Limited.
Olivan GG. What can be done to prevent violence and abuse of children with disabilities?. [Article in Spanish]. Anales de Pediatria. 2005;62(2):153-157. [pmid: 15701312].
Olson HC, Jirikowic T, Kartin D, Astley S. Responding to the challenge of early intervention for Fetal Alcohol Spectrum Disorders. Infants & Young Children. 2007;20(2):172-189. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
Olson HC, Montague RM. An innovative look at early intervention for children affected by prenatal alcohol exposure. Adubato S, Cohen D, editors. Prenatal alcohol use and FASD: A model standard of diagnosis, assessment and multimodal treatment. 2011:64-107. Oak Park, IL. Bentham Science Publishers.
Olson HC, O'Connor MJ, Fitzgerald HE. Lessons learned from study of the developmental impact of parental alcohol use. Infant Mental Health Journal. 2001;22(3):271-290.
Olson HC, Oti R, Gelo J, Beck S. “Family Matters:” Fetal Alcohol Spectrum Disorders and the family. Developmental Disabilities Research Reviews. 2009;15:235-249. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm. [pmid: 19731388].
Olson HC, Rudo-Stern J, Gendler B. Supporting parents of children with fetal alcohol spectrum disorders, and young children with significant prenatal alcohol exposure. Tremblay RE, Boivin M, Peters RDV, Barr G, editors. Encyclopedia on Early Childhood Development. online. 2011:1-10. Montreal, Quebec. Centre of Excellence for Early Childhood Development and Strategic Knowledge Cluster on Early Child Development. July 5, 2012. http://www.child-encyclopedia.com/documents/Olson-Rudo-Stern-GendlerANGxp1.pdf.
O'Malley KD, Hagerman RJ. Developing clinical practice guidelines for pharmacological interventions with alcohol-affected children. Centers for Disease Control and Prevention, editor. Intervening with Children Affected by Prenatal Alcohol Exposure: Proceedings of a Special Focus Session of the Interagency Coordinating Committee on Fetal Alcohol Syndrome September 10-11, 1998. 1999:145-177. Chevy Chase, MD. National Institute of Alcohol Abuse and Alcoholism.
Oscar-Berman M, Marinlovic K. Alcoholism and the brain: An overview. Alcohol Research & Health. 2003;27(2):125-133. [pmid: 15303622].
Page K. Fetal Alcohol Spectrum—The hidden epidemic in our courts. Juvenile and Family Court Journal. 2001;52(4):21-32.
Page K. The invisible havoc of prenatal alcohol damage. Journal of the Center for Families, Children & the Courts. 2002;4:67-90.
Paley B, O'Connor MJ. Intervention for individuals with Fetal Alcohol Spectrum Disorders: Treatment approaches and case management. Developmental Disabilities Research Reviews. 2009;15:258-267. [pmid: 19731383].
Parker RM, Ratzan SC, Lurie N. Health literacy: A policy challenge for advancing high-quality health care. Health Affairs. 2003;22(4):147-153. [pmid: 12889762].
Parker RN, Saltz RF, Hennessy M. The impact of alcohol beverage container warning labels on alcohol-impaired drivers, drinking drivers and the general population in northern California. Addiction. 1994;89:1639-1651. [pmid: 7866248].
Payne JM, France KE, Henley N, D'Antoine HA, Bartu AE, O'Leary CM, Geehoed E. RE-AIM evaluation of the Alcohol and Pregnancy Project: Educational resources to inform health professionals about prenatal alcohol exposure and Fetal Alcohol Spectrum Disorder. Evaluation & the Health Professions. 2011;34(1):57-80. [pmid: 21292723].
Peadon E, Payne J, Henley N, D'Antoine H, Bartu A, O'Leary C, Elliott EJ. Women's knowledge and attitudes regarding alcohol consumption in pregnancy: A national survey. BMC Public Health. 2010;10:510. [pmid: 20727217].
Pease T, Frantz B. 1994. Your rights and personal safety: An abuse prevention education program to empower adults with disabilities and train service providers. Doylestown, PA. Network of Victim Assistance.
Pei J, Denys K, Hughes J, Rasmussen C. Mental health issues in Fetal Alcohol Spectrum Disorder. Journal of Mental Health. 2011;20(5):438-448. [pmid: 21780939].
Premji S, Benzies K, Serrett K, Hayden KA. Research-based interventions for children and youth with a Fetal Alcohol Spectrum Disorder: Revealing the gap. Child: Care, Health and Development. 2006;33:389-397.
Prochaska J, DiClemente C. Toward a comprehensive model of change. Miller WR, Heather N, editors. Treating Addictive Behaviors: Processes of Change. 1986:3-27. New York. Plenum Press.
Project CHOICES Intervention Research Group. Reducing the risk of alcohol-exposed pregnancies: A study of motivational intervention in community settings. Pediatrics. 2003;111:1131-1135. [pmid: 12728125].
Project CHOICES Research Group. Alcohol-exposed pregnancy: Characteristics associated with risk. American Journal of Preventive Medicine. 2002;23(3):166-173. [pmid: 12350448].
Rasmussen C. Executive functioning and working memory in fetal alcohol spectrum disorder. Alcoholism: Clinical and Experimental Research. 2005;29:1359-1367.
Riggins T, Cacic K, Buckingham-Howes S, Scaletti LA, Salmeron BJ, Black MM. Memory ability and hippocampal volume in adolescents with prenatal drug exposure. Neurotoxicology and Teratology. 2012;34(4):434-441. [pmid: 22652523].
Roberts G, Nanson J. 2000. Best practices: Fetal Alcohol Syndrome/ Fetal Alcohol Effects and the effects of other substance use during pregnancy. Ontario. Health Canada.
Royal College of Physicians of London. Annals of Royal College of Physicians. London, England. 1726:253.
Russell M. New assessment tools for risk drinking during pregnancy. Alcohol Health & Research World. 1994;18(1):55-61.
Russell M, Czarnecki DM, Cowan R, McPherson E, Mudar PJ. Measures of maternal alcohol use as predictors of development in early childhood. Alcoholism: Clinical & Experimental Research. 1991;15(6):991-1000.
Russell M, Martier SS, Sokol RJ, Mudar P, Jacobson S, Jacobson J. Detecting risk drinking during pregnancy: A comparison of four screening questionnaires. American Journal of Public Health. 1996;86(10):1435-1439. [pmid: 8876514].
Rutman D. 2011. Substance using women with FASD and FASD prevention: Service providers' perspectives on promising approaches in substance use treatment and care for women with FASD. Victoria, British Columbia. University of Victoria.
Salmon J. Fetal Alcohol Spectrum Disorder: New Zealand birth mothers' experiences. Canadian Journal of Clinical Pharmacology. 2008;15(2):e191-e213. [pmid: 18515921].
Sampson PD, Bookstein FL, Barr HM, Streissguth AP. Prenatal alcohol exposure, birthweight, and measures of child size from birth to age 14 years. American Journal of Public Health. 1994;84(9):1421-1428. [pmid: 8092365].
Sampson PD, Streissguth AP, Bookstein FL, Little RE, Clarren SK, Dehaene P, Graham JM. Incidence of Fetal Alcohol Syndrome and prevalence of Alcohol-Related Neurodevelopmental Disorder. Teratology. 1997;56(5):317-326. [pmid: 9451756].
Sarkar M, Burnett M, Carriere S, Cox LV, Dell CA, Gammon H, Wood R. Screening and recording of alcohol use among women of child-bearing age and pregnant women. The Canadian Journal of Clinical Pharmacology. 2009;16(1):e242-e263. [pmid: 19372602].
Savage C, Wray J, Ritchey PN, Sommers M, Dyehouse J, Fulmer M. Current screening instruments related to alcohol consumption in pregnancy and a proposed alternative method. Journal of Obstetric, Gynecologic, & Neonatal Nursing. 2003;32(4):437-446.
Schmucker CA. Case managers and independent living instructors: Practical hints and suggestions for adults with FAS. Streissguth A, Kanter J, editors. The Challenge of Fetal Alcohol Syndrome: Overcoming Secondary Disabilities. 1997:96-101. Seattle. University of Washington Press.
Schonfeld AM, Mattson SN, Riley EP. Moral maturity and delinquency after prenatal alcohol exposure. Journal of Studies on Alcohol and Drugs. 2005;66(4):545-554.
Schonfeld AM, Paley B, Frankel F, O'Connor MH. Executive functioning predicts social skills following prenatal alcohol exposure. Child Neuropsychology. 2006;12(6):439-452. [pmid: 16952889].
Seale JP, Boltri JM, Shellenberger S, Velasquez MM, Cornelius M, Guyinn M, Okosun I, Sumner H. Primary care validation of a single screening question for drinkers. Journal of Studies on Alcohol and Drugs. 2006;67(5):778-784.
Shor S, Nulman I, Kulaga V, Koren G. Heavy in utero ethanol exposure is associated with the use of other drugs of abuse in a high-risk population. Alcohol. 2010;44(7):623-627. [pmid: 20031369].
Shults RA, Elder RW, Sleet DA, Nichols JL, Alao MO, Carande-Kulis VG, the Task Force on Community Preventive Services. Reviews of evidence regarding interventions to reduce alcohol-impaired driving. American Journal of Preventive Medicine. 2001;21(4S):66-88. [pmid: 11691562].
Silverman AB, Reinherz HZ, Giaconia RM. The long-term sequelae of child and adolescent abuse: A longitudinal community study. Child Abuse and Neglect. 1996;20(8):709-723. [pmid: 8866117].
Sokol RJ, Clarren SK. Guidelines for use of terminology describing the impact of prenatal alcohol on the offspring. Alcoholism: Clinical and Experimental Research. 1989;13(4):597-598.
Sokol RJ, Delaney-Black V, Nordstrom B. Fetal Alcohol Spectrum Disorder. JAMA. 2003;290(22):2996-2999. [pmid: 14665662].
Sokol RJ, Martier SS, Ager JW. The T-ACE questions: Practical prenatal detection of risk drinking. American Journal of Obstetrics and Gynecology. 1989;160(4):863-870. [pmid: 2712118].
Spohr HL, Willms J, Steinhausen HC. Fetal Alcohol Spectrum Disorders in young adulthood. Journal of Pediatrics. 2007;150(2):175-179. [pmid: 17236896].
Springer F, Phillips JL. The IOM Model: A tool for prevention planning and implementation. Prevention Tactics. 2006;8(13):1-7.
Springer JF, Phillips JL. 2007. The Institute of Medicine framework and its implication for the advancement of prevention policy, programs and practice. Prevention Policy Paper Series. EMT Associates, Inc. Folsom, CA. January 18, 2012. http://www.ca-sdfsc.org/docs/resources/SDFSC_IOM_Policy.pdf.
Springer KW, Sheridan J, Kuo D, Carnes M. Long-term physical and mental health consequences of childhood physical abuse: Results from a large population-based sample of men and women. Child Abuse & Neglect. 2007;31:517-530. [pmid: 17532465].
Stratton K, Howe C, Battaglia F. the Committee to Study Fetal Alcohol Syndrome. 1996. Fetal Alcohol Syndrome: Diagnosis, epidemiology, prevention and treatment. Washington, DC. National Academy Press.
Streissguth A. 1997. Fetal Alcohol Syndrome: A guide for families and communities. Baltimore. Paul H. Brookes Publishing Co.
Streissguth AP, Barr JK, Bookstein FL. 1996. Understanding the occurrence of secondary disabilities in clients with Fetal Alcohol Syndrome (FAS) and Fetal Alcohol Effects (FAE). University of Washington. Seattle, WA.
Streissguth AP, Bookstein FL, Barr HM, Sampson PD, O'Malley K, Young JK. Risk factors for adverse life outcomes in Fetal Alcohol Syndrome and Fetal Alcohol Effects. Journal of Developmental Behavioral Pediatrics. 2004;25(4):228-238. [pmid: 15308923].
Streissguth AP, O'Malley K. Neuropsychiatric implications and long-term consequences of fetal alcohol spectrum disorders. Seminars in Clinical Neuropsychiatry. 2000;5(3):177-190. [pmid: 11291013].
Sullivan WC. A note on the influence of maternal inebriety on the offspring. Journal of Mental Science. 1899;45:489-503.
Taylor P, Bailey D, Peters R, Stein B. 2009. Substance abuse during pregnancy: Guidelines for screening. Olympia, WA. Washington State Department of Health.
Teicher MD. Wounds that time won't heal: The neurobiology of child abuse. Cerebrum: The Dana Forum on Brain Science. 2000;2(4):50-67.
Ulleland C. The offspring of alcoholic mothers. Annals New York Academy of Sciences. 1972;197:167-169. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
Ulleland C, Wennberg R, Igo R, Smith N. 1970. The offspring of alcoholic mothers. Jersey City, New Jersey. American Pediatric Society and Society for Pediatric Research. July 1, 2012. http://depts.washington.edu/fasdpn/htmls/literature.htm.
U.S. Department of Health and Human Services. 2003. Developing cultural competence in disaster mental health programs: Guiding principles and recommendations. DHHS Pub No (SMA) 3828. Rockville, MD. Center for Mental Health Services, Substance Abuse and Mental Health Services Administration.
Vallone DM, Duke JC, Cullen J, McCausland KL, Allen JA. Evaluation of EX: A national mass media smoking cessation campaign. Research and Practice. 2011;101(2):302-309.
Voas RB, Fell JC. Preventing alcohol-related problems through health policy research. Alcohol Research & Health. 2010;33(1-2):18-28. [pmid: 23579933].
Vogel H, Knight E, Lauded A, Maura S. Double Trouble in recovery: Self-help for people with dual diagnoses. Psychiatric Rehabilitation Journal. 1998;21(4):356-364. [pmid: 17710222].
Wagenaar AC, Murray DM, Toomey TL. Communities Mobilizing for Change on Alcohol (CMCA): Effects of a randomized trial on arrests and traffic crashes. Addiction. 2000;95(2):209-217. [pmid: 10723849].
Wagenaar AC, Salois MJ, Komro KA. Effects of beverage alcohol price and tax levels on drinking: A meta-analysis of 1003 estimates from 112 studies. Addiction. 2009;10(4):179-190. [pmid: 19149811].
Wilkinson GS, Robertson GJ. 2006. WRAT4 Wide Range Achievement Test professional manual. Lutz, FL. Psychological Assessment Resources, Inc.
Williams MS, Shwellenberger S. 1996. How does your engine run? A Leader's guide to the alert program for self-regulation. Albuquerque, NM. Therapy Works Inc.
Williams R, Vinson DC. Validation of a single screening question for problem drinking. The Journal of Family Practice. 2001;50(4):307-312. [pmid: 11300981].
Winn S, Hay I. Transition from school for youths with a disability: Issues and challenges. Disability & Society. 2009;24(1):103-115.
Zlotnick C, Johnson DM, Stout RL, Zywiak WH, Johnson JE, Schneider RJ. Childhood abuse and intake severity in alcohol disorder patients. Journal of Traumatic Stress. 2006;19(6):949-959. [pmid: 17195983].