# General Bibliography

Abrahams IA, Ali O, Davidson L, Evans AC, King JK, Poplawski P, et al. 2010. Philadelphia behavioral health services transformation: Practice guidelines for recovery and resilience oriented treatment. Philadelphia. Department of Behavioral Health & Intellectual Disability Services.
Academy of Traumatology. 2007. Standards of traumatology practice revised (Rep. No 3.1). Tallahassee, FL. Green Cross Foundation.
Achim AM, Maziade M, Raymond E, Olivier D, Merette C, Roy MA. How prevalent are anxiety disorders in schizophrenia? A meta-analysis and critical review on a significant association. Schizophrenia Bulletin. 2011;37:811-821. [pmid: 19959704].
Acierno R, Brady K, Gray M, Kilpatrick DG, Resnick H, Best CL. Psychopathology following interpersonal violence: A comparison of risk factors in older and younger adults. Journal of Clinical Geropsychology. 2002;8:13-23.
Acierno R, Gray M, Best C, Resnick H, Kilpatrick D, Saunders B, et al. Rape and physical violence: Comparison of assault characteristics in older and younger adults in the National Women’s Study. Journal of Traumatic Stress. 2001;14:685-695. [pmid: 11776417].
Acierno R, Kilpatrick DG, Resnick HS, Saunders BE, Best CL. Violent assault, posttraumatic stress disorder, and depression: Risk factors for cigarette use among adult women. Behavior Modification. 1996;20:363-384. [pmid: 8875812].
Acierno R, Ruggiero KJ, Kilpatrick DG, Resnick HS, Galea S. Risk and protective factors for psychopathology among older versus younger adults after the 2004 Florida hurricanes. The American Journal of Geriatric Psychiatry. 2006;14:1051-1059. [pmid: 17035356].
Adams PF, Martinez ME, Vickerie JL. 2010. Summary health statistics for the U. S. population: National Health Interview. (Rep. No 10: 248). Hyattsville, MD. Centers for Disease Control and Prevention, National Center for Health Statistics.
Adams PR, Adams GR. Mount Saint Helens’s ashfall: Evidence for a disaster stress reaction. American Psychologist. 1984;39:252-260. [pmid: 6711993].
Adams RE, Boscarino JA. Differences in mental health outcomes among Whites, African Americans, and Hispanics following a community disaster. Psychiatry. 2005;68:250-265. [pmid: 16253112].
Adams RE, Boscarino JA. A structural equation model of perievent panic and posttraumatic stress disorder after a community disaster. Journal of Traumatic Stress. 2011;24:61-69. [pmid: 21351165].
Adams RE, Figley CR, Boscarino JA. The Compassion Fatigue Scale: Its use with social workers following urban disaster. Research on Social Work Practice. 2008;18:238-250. [pmid: 18458750].
Adler AB, Bliese PD, McGurk D, Hoge CW, Castro CA. Battlemind debriefing and battlemind training as early interventions with soldiers returning from iraq: Randomization by platoon. Journal of Consulting and Clinical Psychology. 2009;77:928-940. [pmid: 19803572].
Adler AB, Litz BT, Castro CA, Suvak M, Thomas JL, Burrell L, et al. A group randomized trial of critical incident stress debriefing provided to U.S. peacekeepers. Journal of Traumatic Stress. 2008;21:253-263. [pmid: 18553407].
Administration on Children Youth and Families. 2002. Sexual Abuse among Homeless Adolescents: Prevalence, Correlates, and Sequelae. Washington, DC. Administration for Children and Families.
Advanced Trauma Solutions Inc. 2012. Freedom Steps. Farmington, CT. Advanced Trauma Solutions, Inc.
Adverse childhood experiences reported by adults—Five states 2009. MMWR Morb.Mortal.Wkly Report. 2010;59:1609-1613.
Afifi TO, Asmundson GJG, Taylor S, Jang KL. The role of genes and environment on trauma exposure and posttraumatic stress disorder symptoms: A review of twin studies. Clinical Psychology Review. 2010;30:101-112. [pmid: 19892451].
AfterDeployment.org. 2010. Trauma triggers and memories—Overview Joint Base. Lewis–McChord, WA. National Center for Telehealth & Technology.
AfterDeployment.org. 2010. Understanding resilience Joint Base. Lewis–McChord, WA. National Center for Telehealth & Technology.
Agaibi CE, Wilson JP. Trauma, PTSD, and resilience: A review of the literature. Trauma, Violence, & Abuse. 2005;6:195-216.
Agani F, Landau J, Agani N. Community-building before, during, and after times of trauma: The application of the LINC model of community resilience in Kosovo. American Journal of Orthopsychiatry. 2010;80:143-149. [pmid: 20397999].
Agorastos A, Marmar CR, Otte C. Immediate and early behavioral interventions for the prevention of acute and posttraumatic stress disorder. Current Opinion in Psychiatry. 2011;24:526-532. [pmid: 21941180].
Ahmed AS. Post-traumatic stress disorder, resilience and vulnerability. Advances in Psychiatric Treatment. 2007;13:369-375.
Ahmed AT, McCaw BR. Mental health services utilization among women experiencing intimate partner violence. American Journal of Managed Care. 2010;16:731-738. [pmid: 20964469].
Aisenberg E, Ell K. Contextualizing community violence and its effects: An ecological model of parent–child interdependent coping. Journal of Interpersonal Violence. 2005;20:855-871. [pmid: 15914706].
Alarcon LH, Germain A, Clontz AS, Roach E, Nicholas DH, Zenati MS, et al. Predictors of acute posttraumatic stress disorder symptoms following civilian trauma: highest incidence and severity of symptoms after assault. Journal of Trauma and Acute Care Surgery. 2012;72:629-635. [pmid: 22491546].
Alcañiz M, Lozano JA, Rey B. Technological background about VR. Riva G, Botella C, Legeron P, Optale G, editors. Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:199-216. Amsterdam. Ios Press.
Alegría M, Canino G, Shrout PE, Woo M, Duan N, Vila D, et al. Prevalence of mental illness in immigrant and non-immigrant U.S. Latino groups. American Journal of Psychiatry. 2008;165:359-369. [pmid: 18245178].
Alim TN, Feder A, Graves RE, Wang Y, Weaver J, Westphal M, et al. Trauma, resilience, and recovery in a high-risk African–American population. American Journal of Psychiatry. 2008;165:1566-1575. [pmid: 19015233].
Alim TN, Graves E, Mellman TA, Aigbogun N, Gray E, Lawson W, et al. Trauma exposure, posttraumatic stress disorder and depression in an African-American primary care population. Journal of the National Medical Association. 2006;98:1630-1636. [pmid: 17052054].
Allen B, Brymer MJ, Steinberg AM, Vernberg EM, Jacobs A, Speier AH, et al. Perceptions of psychological first aid among providers responding to Hurricanes Gustav and Ike. Journal of Traumatic Stress. 2010;23:509-513. [pmid: 20623598].
Allen JG. 2001. Traumatic relationships and serious mental disorders. New York. John Wiley & Sons Ltd.
Alonso J, Buron A, Bruffaerts R, He Y, Posada–Villa J, Lepine JP, et al. Association of perceived stigma and mood and anxiety disorders: Results from the World Mental Health Surveys. Acta Psychiatrica Scandinavica. 2008;118:305-314. [pmid: 18754833].
Al-Saffar S, Borga P. Focusing on trauma and PTSD in general psychiatric services—Could outcome be improved?. Kume GD, editor. Posttraumatic stress: New research. 2006:147-166. Hauppauge, NY. Nova Science Publishers.
Amaro H, Dai J, Arevalo S, Acevedo A, Matsumoto A, Nieves R, et al. Effects of integrated trauma treatment on outcomes in a racially/ethnically diverse sample of women in urban community-based substance abuse treatment. Journal of Urban Health. 2007;84:508-522. [pmid: 17356904].
American Psychiatric Association. 1980. Diagnostic and statistical manual of mental disorders. 3rd ed. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 1987. Diagnostic and statistical manual of mental disorders. 3rd rev ed. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 1994. Diagnostic and statistical manual of mental disorders. 4th ed. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 2000. Diagnostic and statistical manual of mental disorders. 4th Text Revision ed. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 2000. Position statement on therapies focused on memories of childhood physical and sexual abuse. Arlington, VA. American Psychiatric Association.
American Psychiatric Association. 2010. Practice guideline for the treatment of patients with acute stress disorder and posttraumatic stress disorder. Arlington, VA. American Psychiatric Association.
American Psychiatric Association. 2012. G 03 posttraumatic stress disorder. Arlington, VA. American Psychiatric Association.
American Psychiatric Association. 2012. Proposed draft revisions to DSM disorders and criteria. Arlington, VA. American Psychiatric Association.
American Psychiatric Association. 2013. Diagnostic and statistical manual of mental disorders. 5th ed. Arlington, VA. American Psychiatric Association.
American Psychiatric Association. 2013. Highlights of changes from DSM-IV-TR to DSM-V. Arlington, VA. American Psychiatric Association.
American Psychological Association & The Ad Hoc Committee on Legal and Ethical Issues in the Treatment of Interpersonal Violence. 2003. Potential Problems for Psychologists Working with the Area of Interpersonal Violence. Washington,, DC. American Psychological Association.
Amstadter AB, Acierno R, Richardson LK, Kilpatrick DG, Gros DF, Gaboury MT, et al. Posttyphoon prevalence of posttraumatic stress disorder, major depressive disorder, panic disorder, and generalized anxiety disorder in a Vietnamese sample. Journal of Traumatic Stress. 2009;22:180-188. [pmid: 19455707].
Amstadter AB, Zinzow HM, McCauley JL, Strachan M, Ruggiero KJ, Resnick HS, et al. Prevalence and correlates of service utilization and help seeking in a national college sample of female rape victims. Journal of Anxiety Disorders. 2010;24:900-902. [pmid: 20620018].
Anda RF, Felitti VJ, Brown D, Chapman D, Dong M, Dube SR, et al. Insights into intimate partner violence from the Adverse Childhood Experiences (ACE) Study. The physician’s guide to intimate partner violence and abuse. 2006:77-88. Volcano, CA. Volcano Press.
Anders SL, Shallcross SL, Frazier PA. Beyond Criterion A1: The effects of relational and non-relational traumatic events. Journal of Trauma & Dissociation. 2012;13:134-151. [pmid: 22375804].
Andreasen NC. Posttraumatic stress disorder: A history and a critique. Annals of the New York Academy of Sciences. 2010;1208:67-71. [pmid: 20955327].
Andrews B, Brewin CR, Rose S. Gender, social support, and PTSD in victims of violent crime. Journal of Traumatic Stress. 2003;16:421-427. [pmid: 12895025].
Ansell EB, Pinto A, Edelen MO, Markowitz JC, Sanislow CA, Yen S, et al. The association of personality disorders with the prospective 7-year course of anxiety disorders. Psychological Medicine. 2011;41:1019-1028. [pmid: 20836909].
Antony MM, Orsillo SM, Roemer L. 2001. Practitioner’s guide to empirically based measures of anxiety. New York. Kluwer Academic/Plenum Publishers.
Apter AJ, Garcia LA, Boyd RC, Wang X, Bogen DK, Ten Have T. Exposure to community violence is associated with asthma hospitalizations and emergency department visits. Journal of Allergy and Clinical Immunology. 2010;126:552-557. [pmid: 20816190].
Archambeau OG, Frueh BC, Deliramich AN, Elhai JD, Grubaugh AL, Herman S, et al. Interpersonal violence and mental health outcomes among Asian American and Native Hawaiian/other Pacific Islander college students. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:273-283.
Arkowitz H, Miller WR, Westra HA, Rollnick S. Motivational interviewing in the treatment of psychological problems: Conclusions and future directions. Motivational interviewing in the treatment of psychological problems. 2008:324-342. New York. Guilford Press.
Arredondo P, Bordes V, Paniagua FA. Mexicans, Mexican Americans, Caribbean, and other Latin Americans. Marsella AJ, Johnson JL, Watson P, Gryczynski J, editors. Ethnocultural perspectives on disaster and trauma: Foundations, issues, and applications. 2008:299-320. New York. Springer Publishing Science + Business Media.
Asmundson GJ, Katz J. Understanding the co-occurrence of anxiety disorders and chronic pain: State-of-the-art. Depression and Anxiety. 2009;26:888-901. [pmid: 19691031].
Asmundson GJG, Abrams MP, Collimore KC. Pain and anxiety disorders. Anxiety in health behaviors and physical illness. 2008:207-235. New York. Springer Publishing Science + Business Media.
Asnaani A, Richey JA, Dimaite R, Hinton DE, Hofmann SG. A cross-ethnic comparison of lifetime prevalence rates of anxiety disorders. Journal of Nervous and Mental Disease. 2010;198:551-555. [pmid: 20699719].
Aspelmeier JE, Elliott AN, Smith CH. Childhood sexual abuse, attachment, and trauma symptoms in college women: The moderating role of attachment. Child Abuse & Neglect. 2007;31:549-566. [pmid: 17391758].
Astin MC, Lawrence KJ, Foy DW. Posttraumatic stress disorder among battered women: Risk and resiliency factors. Violence and Victims. 1993;8:17-28. [pmid: 8292561].
Auerbach S. Sleep disorders related to alcohol and other drug use. Graham AW, Schultz TK, Mayo–Smith MF, Ries RK, Wilford BB, editors. Principles of Addiction Medicine. 3rd ed. 2003:1179-1193. Chevy Chase, MD. American Society of Addiction Medicine.
Australian Centre for Posttraumatic Mental Health. 2007. Australian guidelines for the treatment of adults with acute stress disorder and posttraumatic stress disorder. Melbourne, Victoria. Australian Centre for Posttraumatic Mental Health.
Awa WL, Plaumann M, Walter U. Burnout prevention: A review of intervention programs. Patient Education and Counseling. 2010;78:184-190. [pmid: 19467822].
Ayers JW, Hofstetter CR, Usita P, Irvin VL, Kang S, Hovell MF. Sorting out the competing effects of acculturation, immigrant stress, and social support on depression: A report on Korean women in CAornia. Journal of Nervous and Mental Disease. 2009;197:742-747. [pmid: 19829202].
Azeem MW, Aujla A, Rammerth M, Binsfeld G, Jones RB. Effectiveness of six core strategies based on trauma informed care in reducing seclusions and restraints at a child and adolescent psychiatric hospital. Journal of Child and Adolescent Psychiatric Nursing. 2011;24:11-15. [pmid: 21272110].
Babson KA, Feldner MT. Temporal relations between sleep problems and both traumatic event exposure and PTSD: A critical review of the empirical literature. Journal of Anxiety Disorders. 2010;24:1-15. [pmid: 19716676].
Back S, Dansky BS, Coffey SF, Saladin ME, Sonne S, Brady KT. Cocaine dependence with and without posttraumatic stress disorder: A comparison of substance use, trauma history and psychiatric comorbidity. American Journal on Addictions. 2000;9:51-62. [pmid: 10914293].
Baer RA. Mindfulness training as a clinical intervention: A conceptual and empirical review. Clinical Psychology: Science and Practice. 2003;10:125-143.
Baglioni C, Battagliese G, Feige B, Spiegelhalder K, Nissen C, Voderholzer U, et al. Insomnia as a predictor of depression: A meta-analytic evaluation of longitudinal epidemiological studies. Journal of Affective Disorders. 2011;135:10-19. [pmid: 21300408].
Bailey HN, DeOliveira CA, Wolfe VV, Evans EM, Hartwick C. The impact of childhood maltreatment history on parenting: A comparison of maltreatment types and assessment methods. Child Abuse & Neglect. 2012;36:236-246. [pmid: 22444714].
Bailey K, Webster R, Baker AL, Kavanagh DJ. 2011. Exposure to dysfunctional parenting and trauma events and posttraumatic stress profiles among a treatment sample with coexisting depression and alcohol use problems. Drug Alcohol Revjew.
Baker DG, Nash WP, Litz BT, Geyer MA, Risbrough VB, Nievergelt CM, et al. Predictors of risk and resilience for posttraumatic stress disorder among ground combat marines: Methods of the Marine Resiliency Study. Preventing Chronic Disease. 2012;9:E97. [pmid: 22575082].
Baker KG, Gippenreiter JB. Stalin’s purge and its impact on Russian families: A pilot study. Danieli Y, editor. International handbook of multigenerational legacies of trauma. 1998:403-434. New York. Plenum Press.
Balsam KF, Lehavot K, Beadnell B, Circo E. Childhood abuse and mental health indicators among ethnically diverse lesbian, gay, and bisexual adults. Journal of Consulting and Clinical Psychology. 2010;78:459-468. [pmid: 20658803].
Balsam KF, Rothblum ED, Beauchaine TP. Victimization over the life span: A comparison of lesbian, gay, bisexual, and heterosexual siblings. Journal of Consulting and Clinical Psychology. 2005;73:477-487. [pmid: 15982145].
Baños RM, Guillen V, Quero S, Garcia-Palacios A, Alcañiz M, Botella C. A virtual reality system for the treatment of stress-related disorders: A preliminary analysis of efficacy compared to a standard cognitive behavioral program. International Journal of Human Computer Studies. 2011;69:602-613.
Banyard VL, Williams LM, Siegel JA. Childhood Sexual Abuse: A Gender Perspective on Context and Consequences. Child Maltreatment. 2004;9:223-238. [pmid: 15245676].
Baranowsky AB, Young M, Johnson-Douglas S, Williams-Keeler L, McCarrey M. PTSD transmission: A review of secondary traumatization in Holocaust survivor families. Canadian Psychology/Psychologie canadienne. 1998;39:247-256.
Barner JR, Carney MM. Interventions for intimate partner violence: A historical review. Journal of Family Violence. 2011;26:235-244.
Barnes M, Figley CR. Family therapy: Working with traumatized families. Lebow JL, editor. Handbook of clinical family therapy. 2005:309-326. Hoboken, NJ. John Wiley and Sons, Inc.
Baroody AN. Spirituality and trauma during a time of war: A systemic approach to pastoral care and counseling. Families under fire: Systemic therapy with military families. 2011:165-190. New York. Routledge/Taylor & Francis Group.
Bartone PT, Roland RR, Picano JJ, Williams T. Psychological hardiness predicts success in US Army special forces candidates. International Journal of Selection and Assessment. 2008;16:78-81.
Başoğlu M, Livanou M, Crnobaric C, Franciskovic T, Suljic E, Duric D, et al. Psychiatric and cognitive effects of war in former Yugoslavia: Association of lack of redress for trauma and posttraumatic stress reactions. JAMA. 2005;294:580-590. [pmid: 16077052].
Başoğlu M, Salcioglu E, Livanou M. A randomized controlled study of single-session behavioural treatment of earthquake-related post-traumatic stress disorder using an earthquake simulator. Psychological Medicine. 2007;37:203-213. [pmid: 17254365].
Batten SV, Hayes SC. Acceptance and commitment therapy in the treatment of comorbid substance abuse and post-traumatic stress disorder: A case study. Clinical Case Studies. 2005;4:246-262.
Beals J, Manson SM, Shore JH, Friedman MJ, Ashcraft M, Fairbank JA, et al. The prevalence of posttraumatic stress disorder among American Indian Vietnam veterans: Disparities and context. Journal of Traumatic Stress. 2002;15:89-97. [pmid: 12013069].
Beals J, Manson SM, Whitesell NR, Spicer P, Novins DK, Mitchell CM. Prevalence of DSM-IV disorders and attendant help–seeking in 2 American Indian reservation populations. Archives of General Psychiatry. 2005;62:99-108. [pmid: 15630077].
Beals J, Novins DK, Whitesell NR, Spicer P, Mitchell CM, Manson SM. Prevalence of mental disorders and utilization of mental health services in two American Indian reservation populations: Mental health disparities in a national context. American Journal of Psychiatry. 2005;162:1723-1732. [pmid: 16135633].
Beard C, Weisberg RB, Keller MB. Health-related quality of life across the anxiety disorders: findings from a sample of primary care patients. Journal of Anxiety Disorders. 2010;24:559-564. [pmid: 20418054].
Beattie N, Shannon C, Kavanagh M, Mulholland C. Predictors of PTSD symptoms in response to psychosis and psychiatric admission. Journal of Nervous and Mental Disease. 2009;197:56-60. [pmid: 19155811].
Bebbington PE, Bhugra D, Brugha T, Singleton N, Farrell M, Jenkins R, et al. Psychosis, victimisation and childhood disadvantage: evidence from the second British National Survey of Psychiatric Morbidity. British Journal of Psychiatry. 2004;185:220-226. [pmid: 15339826].
Beck AT. 1993. Beck anxiety inventory. San Antonio, TX. The Psychological Corporation.
Beck AT, Emery G, Greenberg RL. 2005. Anxiety disorders and phobias: A cognitive perspective. New York. Basic Books.
Beck AJ, Harrison PM, Berzofsky M, Caspar R, Krebs C. 2010. Sexual victimization in prisons and jails reported by inmates, 2008–09. Washington,, DC. Bureau of Justice Statistics, U.S. Department of Justice.
Beck AT, Rush AJ, Shaw BF, Emery G. 1979. Cognitive Therapy of Depression. New York, N.Y. Guilford Press.
Beck AT, Steer RA, Brown GK. 1996. Beck Depression Inventory – II Manual. San Antonio, TX. The Psychological Corporation.
Beck AT, Wright FD, Newman CF, Liese BF. 1993. Cognitive Therapy of Substance Abuse. New York. Guilford Press.
Beck CT. Secondary traumatic stress in nurses: A systematic review. Archives of Psychiatric Nursing. 2011;25:1-10. [pmid: 21251596].
Beck JG, Coffey SF, Foy DW, Keane TM, Blanchard EB. Group cognitive behavior therapy for chronic posttraumatic stress disorder: An initial randomized pilot study. BehavTher. 2009;40:82-92.
Becker MA, Noether CD, Larson MJ, Gatz M, Brown V, Heckman JP, et al. Characteristics of women engaged in treatment for trauma and co-occurring disorders: Findings from a national multisite study. Journal of Community Psychology. 2005;33:429-443.
Beidel DC, Frueh BC, Uhde TW, Wong N, Mentrikoski JM. Multicomponent behavioral treatment for chronic combat-related posttraumatic stress disorder: A randomized controlled trial. Journal of Anxiety Disorders. 2011;25:224-231. [pmid: 20951543].
Beiser M, Wickrama KAS. Trauma, time and mental health: A study of temporal reintegration and depressive disorder among Southeast Asian refugees. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2004;34:899-910.
Bell CC. Trauma, culture, and resiliency. Southwick SM, Litz BT, Charney D, Friedman MJ, editors. Resilience and mental health: Challenges across the lifespan. 2011:176-187. New York. Cambridge University Press.
Bell H, Kulkarni S, Dalton L. Organizational prevention of vicarious trauma. Families in Society. 2003;84:463-470.
Bell NS, Amoroso PJ, Yore MM, Smith GS, Jones BH. Self-reported risk-taking behaviors and hospitalization for motor vehicle injury among active duty army personnel. American Journal of Preventive Medicine. 2000;18:85-95. [pmid: 10736544].
Benedek DM, Ursano RJ. Posttraumatic stress disorder: From phenomenology to clinical practice. FOCUS: The Journal of Lifelong Learning in Psychiatry. 2009;7:160-175.
Benedek DM, Friedman MJ, Zatzick D, Ursano RJ. Guideline watch (March 2009): Practice guideline for the treatment of patients with acute stress disorder and posttraumatic stress disorder. FOCUS: The Journal of Lifelong Learning in Psychiatry. 2009;VII:204-213.
Benish SG, Imel ZE, Wampold BE. The relative efficacy of bona fide psychotherapies for treating post-traumatic stress disorder: A meta-analysis of direct comparisons. Clinical Psychology Review. 2008;28:746-758. [pmid: 18055080].
Bent-Goodley TB. Culture and domestic violence: Transforming knowledge development. Journal of Interpersonal Violence. 2005;20:195-203. [pmid: 15601792].
Bent-Goodley TB. Health disparities and violence against women: Why and how cultural and societal influences matter. Trauma, Violence, & Abuse. 2007;8:90-104.
Ben-Zur H. Personal resources of mastery–optimism, and communal support beliefs, as predictors of posttraumatic stress in uprooted Israelis. Anxiety Stress Coping. 2008;21:295-307. [pmid: 18938288].
Berceli D, Napoli M. A proposal for a mindfulness-based trauma prevention program for social work professionals. Complementary Health Practice Review. 2006;11:153-165.
Berg G. The relationship between spiritual distress, PTSD and depression in Vietnam combat veterans. Journal of Pastoral Care and Counseling. 2011;65:6-11. [pmid: 21919327].
Berger W, Mendlowicz MV, Marques-Portella C, Kinrys G, Fontenelle LF, Marmar CR, et al. Pharmacologic alternatives to antidepressants in posttraumatic stress disorder: A systematic review. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2009;33:169-180. [pmid: 19141307].
Berkowitz SJ, Stover CS, Marans SR. The Child and Family Traumatic Stress Intervention: Secondary prevention for youth at risk of developing PTSD. Journal of Child Psychology and Psychiatry. 2011;52:676-685. [pmid: 20868370].
Bernard JM, Goodyear RK. 2009. Fundamentals of clinical supervision. 4th ed. Upper Saddle River, NJ. Merrill/Pearson.
Bernstein DP. Childhood trauma and drug addiction: Assessment, diagnosis, and treatment. Alcoholism Treatment Quarterly. 2000;18:19-30.
Bernstein EM, Putnam FW. Development, reliability, and validity of a dissociation scale. Journal of Nervous and Mental Disease. 1986;174:727-735. [pmid: 3783140].
Bhugra D. Migration and depression. Acta Psychiatrica Scandinavica. 2003;108:67-72. [pmid: 12956818].
Bills LJ. Using trauma theory and S.A.G.E. in outpatient psychiatric practice. Psychiatric Quarterly. 2003;74:191-203. [pmid: 12602833].
Birman D, Tran N. Psychological distress and adjustment of Vietnamese refugees in the United States: Association with pre– and postmigration factors. American Journal of Orthopsychiatry. 2008;78:109-120. [pmid: 18444733].
Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2007:CD003388. [pmid: 17636720].
Bisson JI, Ehlers A, Matthews R, Pilling S, Richards D, Turner S. Psychological treatments for chronic post-traumatic stress disorder: Systematic review and meta-analysis. British Journal of Psychiatry. 2007;190:97-104. [pmid: 17267924].
Blackburn C. 1995. November. Family and relapse. Counselor. Alexandria, VA. National Association of Alcoholism and Drug Abuse Counselors.
Blake D, Weathers F, Nagy L, Koloupek D, Klauminzer G, Charney D, et al. 1990. Clinician administered PTSD scale (CAPS). Boston. National Center for Post-Traumatic Stress Disorder.
Blanchard EB, Hickling EJ. Determining who develops PTSD from MVAs. After the crash: Psychological assessment and treatment of survivors of motor vehicle accidents. 2nd ed. 2004:99-124. Washington, DC. American Psychological Association.
Blanchard EB, Buckley TC, Hickling EJ, Taylor AE. Posttraumatic stress disorder and comorbid major depression: Is the correlation an illusion?. Journal of Anxiety Disorders. 1998;12:21-37. [pmid: 9549607].
Blanco C. Epidemiology of PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:49-74. Chichester, UK. John Wiley & Sons.
Bleich A, Gelkopf M, Solomon Z. Exposure to terrorism, stress-related mental health symptoms, and coping behaviors among a nationally representative sample in Israel. Journal of the American Medical Association. 2003;290:612-620. [pmid: 12902364].
Bleich A, Gelkopf M, Melamed Y, Solomon Z. Mental health and resiliency following 44 months of terrorism: A survey of an Israeli national representative sample. BMC Medicine. 2006;4:21. [pmid: 16934160].
Bliss MJ, Cook SL, Kaslow NJ. An ecological approach to understanding incarcerated women’s responses to abuse. Women & Therapy. 2007;29:97-115.
Block SH, Block CB. Improve everyday life by melting away your tension. Mind–body workbook for PTSD. 2010:21-43. Oakland, CA. New Harbinger Publications, Inc.
Block SH, Block CB. 2010. Mind–body workbook for PTSD: A 10-week program for healing after trauma. Oakland, CA. New Harbinger Publications, Inc.
Block SH, Block CB. Self-discovery and self-healing of PTSD. Mind–body workbook for PTSD. 2010:6-20. Oakland, CA. New Harbinger Publications, Inc.
Blomstedt Y, Johansson SE, Sundquist J. Mental health of immigrants from the former Soviet Bloc: A future problem for primary health care in the enlarged European Union? A cross-sectional study. BMC Public Health. 2007;7:27. [pmid: 17328817].
Bloom SL, Farragher B. 2011. Destroying sanctuary: The crisis in human service delivery systems. New York. Oxford University Press.
Bloom SL. 1997. Creating sanctuary: Toward the evolution of sane societies. New York. Routledge.
Bloom SL. Organizational stress and trauma-informed services. A public health perspective of women’s mental health. 2010:295-311. New York. Springer Publishing Science + Business Media.
Bloom SL, Bennington-Davis M, Farragher B, McCorkle D, Nice-Martini K, Wellbank K. Multiple opportunities for creating sanctuary. Psychiatric Quarterly. 2003;74:173-190. [pmid: 12602832].
Bloom SL, Foderaro JF, Ryan R. 2006. S.E.L.F.: A trauma-informed psychoeducational group curriculum. Retrieved on July 4, 2013, from: http://www.sanctuaryweb.com/self-manual.php.
Bober T, Regehr C. Strategies for reducing secondary or vicarious trauma: Do they work?. Brief Treatment and Crisis Intervention. 2006;6:1-9.
Bonanno GA, Mancini AD. Toward a lifespan approach to resilience and potential trauma. Southwick SM, Litz BT, Charney D, Friedman MJ, editors. Resilience and mental health: Challenges across the lifespan. 2011:120-134. New York. Cambridge University Press.
Bonanno GA. Loss, trauma, and human resilience: Have we underestimated the human capacity to thrive after extremely aversive events?. American Psychologist. 2004;29:20-28. [pmid: 14736317].
Bonanno GA, Galea S, Bucciarelli A, Vlahov D. What predicts psychological resilience after disaster? The role of demographics, resources, and life stress. Journal of Consulting & Clinical Psychology. 2007;75:671-682. [pmid: 17907849].
Bonow JT, Follette WC. A functional analytic conceptualization of retraumatization: Implications for clinical assessment. Duckworth MP, editor. Retraumatization: Assessment, treatment, and prevention. 2012:129-162. New York. Routledge/Taylor & Francis Group.
Booth BM, Mengeling M, Torner J, Sadler AG. Rape, sex partnership, and substance use consequences in women veterans. Journal of Traumatic Stress. 2011;24:287-294. [pmid: 21567476].
Bormann JE, Liu L, Thorp SR, Lang AJ. 2011. Spiritual wellbeing mediates PTSD change in veterans with military-related PTSD. IntJBehavMed.
Boscarino JA, Adams RE. Peritraumatic panic attacks and health outcomes two years after psychological trauma: Implications for intervention and research. Psychiatry Research. 2009;167:139-150. [pmid: 19339055].
Boscarino JA, Figley CR, Adams RE. Compassion fatigue following the September 11 terrorist attacks: A study of secondary trauma among New York City social workers. International Journal of Emergency Mental Health. 2004;6:57-66. [pmid: 15298076].
Boscarino JA, Kirchner HL, Hoffman SN, Sartorius J, Adams RE, Figley CR. A brief screening tool for assessing psychological trauma in clinical practice: Development and validation of the New York PTSD Risk Score. General Hospital Psychiatry. 2011;33:489-500. [pmid: 21777981].
Boscarino JA, Kirchner HL, Hoffman SN, Sartorius J, Adams RE, Figley CR. A brief screening tool for assessing psychological trauma in clinical practice: Development and validation of the New York PTSD Risk Score. General Hospital Psychiatry. 2011;33:489-500. [pmid: 21777981].
Boscarino JA, Kirchner HL, Hoffman SN, Sartorius J, Adams RE, Figley CR. Predicting future PTSD using a modified New York Risk Score: Implications for patient screening and management. Minerva Psichiatrica. 2012;53:47-59. [pmid: 22408285].
Boscarino JA, Kirchner HL, Hoffman SN, Sartorius J, Adams RE, Figley CR. 2012. The New York PTSD Risk Score for assessment of psychological trauma: Male and female versions. Psychiatry Research.
Bosquet EM, Kitts RL, Blood E, Bizarro A, Hofmeister M, Wright RJ. Maternal posttraumatic stress symptoms and infant emotional reactivity and emotion regulation. Infant Behavior & Development. 2011;34:487-503. [pmid: 21862136].
Botella C, Quero S, Baños RM, Perpina C, Garcia Palacios A, Riva G. Virtual reality and psychotherapy. Riva G, Botella C, Legeron P, Optale G, editors. Internet and virtual reality as assessment and rehabilitation tools for clinical psychology and neuroscience. 2004:37-54. Amsterdam. Ios Press.
Böttche M, Kuwert P, Knaevelsrud C. Posttraumatic stress disorder in older adults: An overview of characteristics and treatment approaches. International Journal of Geriatric Psychiatry. 2012;27:230-239. [pmid: 21538540].
Bourque LB, Shen H. Psychometric characteristics of Spanish and English versions of the Civilian Mississippi scale. Journal of Traumatic Stress. 2005;18:719-728. [pmid: 16382438].
Bovin MJ, Marx BP. The importance of the peritraumatic experience in defining traumatic stress. Psychological Bulletin. 2011;137:47-67. [pmid: 21090886].
Bowman CG, Mertz E. A dangerous direction: Legal intervention in sexual abuse survivor therapy. Harvard Law Review. 1996;109:551-639.
Bowman ML, Yehuda R. Risk factors and the adversity–stress model. Rosen GM, editor. Posttraumatic stress disorder: Issues and controversies. 2004:15-38. New York. John Wiley & Sons, Inc.
Braakman MH, Kortmann FA, van den Brink W. Validity of ‘post-traumatic stress disorder with secondary psychotic features’: A review of the evidence. Acta Psychiatrica Scandinavica. 2009;119:15-24. [pmid: 18764840].
Bradley R, Greene J, Russ E, Dutra L, Westen D. A multidimensional meta-analysis of psychotherapy for PTSD. American Journal of Psychiatry. 2005;162:214-227. [pmid: 15677582].
Bradley R, Schwartz AC, Kaslow NJ. Posttraumatic stress disorder symptoms among low-income, African American women with a history of intimate partner violence and suicidal behaviors: Self-esteem, social support, and religious coping. Journal of Traumatic Stress. 2005;18:685-696. [pmid: 16382436].
Brady KT, Killeen TK, Brewerton T, Lucerini S. Comorbidity of psychiatric disorders and posttraumatic stress disorder. Journal of Clinical Psychiatry. 2000;61:22-32. [pmid: 10795606].
Brady KT, Killeen T, Saladin ME, Dansky B, Becker S. Comorbid substance abuse and posttraumatic stress disorder: Characteristics of women in treatment. American Journal on Addictions. 1994;3:160-164.
Brave Heart MYH. Gender differences in the historical trauma response among the Lakota. Journal of Health & Social Policy. 1999;10:1-20. [pmid: 10538183].
Brave Heart MYH. The historical trauma response among natives and its relationship with substance abuse: A Lakota illustration. Journal of Psychoactive Drugs. 2003;35:7-13. [pmid: 12733753].
Brave Heart MYH. The historical trauma response among natives and its relationship to substance abuse: A Lakota illustration. Nebelkopf E, Phillips M, editors. Healing and mental health for Native Americans: Speaking in red. 2004:7-18. Walnut Creek, CA. AltaMira Press.
Breh DC, Seidler GH. Is peritraumatic dissociation a risk factor for PTSD?. Journal of Trauma & Dissociation. 2007;8:53-69. [pmid: 17409054].
Brenner LA. Neuropsychological and neuroimaging findings in traumatic brain injury and post-traumatic stress disorder. Dialogues in Clinical Neuroscience. 2011;13:311-323. [pmid: 22034217].
Breno AL, Galupo MP. Sexual abuse histories of young women in the U.S. child welfare system: A focus on trauma-related beliefs and resilience. Journal of Child Sexual Abuse. 2007;16:97-113. [pmid: 17895234].
Breslau N. Gender differences in trauma and posttraumatic stress disorder. Journal of Gender Specific Medicine. 2002;5:34-40. [pmid: 11859685].
Breslau N, Davis GC, Andreski P, Peterson E. Traumatic events and posttraumatic stress disorder in an urban population of young adults. Archives of General Psychiatry. 1991;48:216-222. [pmid: 1996917].
Breslau N, Davis C, Peterson EL, Schultz L. A second look at comorbidity in victims of trauma: The posttraumatic stress disorder–major depression connection. Biological Psychiatry. 2000;48:902-909. [pmid: 11074228].
Breslau N, Davis GC, Schultz LR. Posttraumatic stress disorder and the incidence of nicotine, alcohol, and other drug disorders in persons who have experienced trauma. Archives of General Psychiatry. 2003;60:289-294. [pmid: 12622662].
Breslau N, Lucia VC, Alvarado GF. Intelligence and other predisposing factors in exposure to trauma and posttraumatic stress disorder: A follow-up study at age 17 years. Archives of General Psychiatry. 2006;63:1238-1245. [pmid: 17088504].
Breslau N, Lucia VC, Davis GC. Partial PTSD versus full PTSD: An empirical examination of associated impairment. Psychological Medicine. 2004;34:1205-1214. [pmid: 15697047].
Brewerton TD. Eating disorders, trauma, and comorbidity: Focus on PTSD. Journal of Eating Disorders. 2007;15:285-304.
Brewin CR. Remembering and forgetting. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:116-134. New York. Guilford Press.
Brewin CR. The nature and significance of memory disturbance in posttraumatic stress disorder. Annual Review of Clinical Psychology. 2011;7:203-227.
Brewin CR. Walking the line in defining PTSD: Comprehensiveness versus core features. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:35-37. Chichester, UK. John Wiley and Sons, Inc.
Brewin CR, Andrews B, Valentine JD. Meta-analysis of risk factors for posttraumatic stress disorder in trauma-exposed adults. Journal of Consulting and Clinical Psychology. 2000;68:748-766. [pmid: 11068961].
Bride BE. Prevalence of secondary traumatic stress among social workers. Social Work. 2007;52:63-70. [pmid: 17388084].
Bride BE, Robinson MM, Yegidis B, Figley CR. Development and validation of the Secondary Traumatic Stress Scale. Research on Social Work Practice. 2004;14:27-35.
Bridges AJ, de Arellano MA, Rheingold AA, Danielson CK, Silcott L. Trauma exposure, mental health, and service utilization rates among immigrant and United States-born Hispanic youth: Results from the Hispanic family study. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:40-48.
Briere J. 1995. Trauma symptom inventory professional manual. Odessa, FL. Psychological Assessment Resources.
Briere J. 1996. Therapy for adults molested as children: Beyond survival. 2nd ed. New York. Springer Publishing Publishing.
Briere J. 1996. Trauma symptom checklist for children professional manual. Odessa, FL. Psychological Assessment Resources.
Briere J. 1997. Psychological assessment of adult posttraumatic states. 1st ed. Washington, DC. American Psychological Association.
Briere J. 2001. Detailed assessment of posttraumatic stress: Professional manual. Odessa, FL. Psychological Assessment Resources.
Briere J, Scott C. Central issues in trauma treatment. Principles of trauma therapy: A guide to symptoms, evaluation, and treatment. 2006:67-85. Thousand Oaks, CA. Sage Publications.
Briere J, Scott C. 2006. Principles of trauma therapy: A guide to symptoms, evaluation, and treatment. Thousand Oaks, CA. Sage Publications.
Briere J, Spinazzola J. Assessment of the sequelae of complex trauma: Evidence-based measures. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:104-123. New York. Guilford Press.
Brohawn KH, Offringa R, Pfaff DL, Hughes KC, Shin LM. The neural correlates of emotional memory in posttraumatic stress disorder. Biological Psychiatry. 2010;68:1023-1030. [pmid: 20855060].
Bronfenbrenner U, Ceci SJ. Nature–nurture reconceptualized in developmental perspective: A bioecological model. Psychological Review. 1994;101:568-586. [pmid: 7984707].
Bronfenbrenner U. 1979. The ecology of human development: Experiments by nature and design. Cambridge, Mass. Harvard University Press.
Brooks R, Silove D, Bryant R, O’Donnell M, Creamer M, McFarlane A. A confirmatory factor analysis of the acute stress disorder interview. Journal of Traumatic Stress. 2008;21:352-355. [pmid: 18553413].
Brown D. Assessment of attachment and abuse history, and adult attachment style. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:124-144. New York. Guilford Press.
Brown LM, Shiang J, Bongar B. Crisis intervention. Handbook of psychology: Clinical psychology. 2003;8:431-451. Hoboken. John Wiley and Sons, Inc.
Brown LS. Entering the healing process. Cultural competence in trauma therapy: Beyond the flashback. 2008:61-93. Washington, DC. American Psychological Association.
Brown LS. Feminist therapy. Lebow JL, editor. Twenty-first century psychotherapies: Contemporary approaches to theory and practice. 2008:277-306. Hoboken, NJ. John Wiley and Sons, Inc.
Brown LS. Cultural competence. Courtois CA, Ford JD, editors. Treating complex traumatic stress disorders: An evidence-based guide. 2009:166-182. New York. Guilford Press.
Brown PJ, Read JP, Kahler CW. Comorbid posttraumatic stress disorder and substance use disorders: Treatment outcomes and the role of coping. Ouimette P, Brown PJ, editors. Trauma and Substance Abuse: Causes, Consequences, and Treatment of Comorbid Disorders. 2003:171-188. Washington, DC. American Psychological Association.
Brown PJ, Stout RL, Gannon-Rowley J. Substance use disorder–PTSD comorbidity: Patients’ perceptions of symptom interplay and treatment issues. Journal of Substance Abuse Treatment. 1998;15:445-448. [pmid: 9751003].
Brown TA, Campbell LA, Lehman CL, Grisham JR, Mancill RB. Current and lifetime comorbidity of the DSM-IV anxiety and mood disorders in a large clinical sample. Journal of Abnormal Psychology. 2001;110:585-599. [pmid: 11727948].
Bryant R. Post-traumatic stress disorder vs. traumatic brain injury. Dialogues in Clinical Neuroscience. 2011;13:251-262. [pmid: 22034252].
Bryant RA, Harvey AG. 2000. Acute stress disorder: A handbook of theory, assessment, and treatment. 1st ed. Washington, DC. American Psychological Association.
Bryant RA, Harvey AG. Gender differences in the relationship between acute stress disorder and posttraumatic stress disorder following motor vehicle accidents. Australian and New Zealand Journal of Psychiatry. 2003;37:226-229. [pmid: 12656964].
Bryant RA, Litz BT. Intermediate Interventions. Ritchie EC, Watson PJ, Friedman MJ, editors. Interventions following mass violence and disasters: Strategies for mental health practice. 2006:155-173. New York. Guilford Press.
Bryant RA. Acute stress disorder as a predictor of posttraumatic stress disorder: A systematic review. Journal of Clinical Psychiatry. 2011;72:233-239. [pmid: 21208593].
Bryant RA. Psychological interventions for trauma exposure and PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:171-202. Chichester, UK. John Wiley & Sons.
Bryant RA, Creamer M, O’Donnell M, Silove D, McFarlane AC. Heart rate after trauma and the specificity of fear circuitry disorders. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2011;41:2573-2580.
Bryant RA, Felmingham KL, Falconer EM, Pe BL, Dobson-Stone C, Pierce KD, et al. Preliminary evidence of the short allele of the serotonin transporter gene predicting poor response to cognitive behavior therapy in posttraumatic stress disorder. Biological Psychiatry. 2010;67:1217-1219. [pmid: 20434135].
Bryant RA, Harvey AG, Guthrie RM, Moulds ML. Acute psychophysiological arousal and posttraumatic stress disorder: A two-year prospective study. Journal of Traumatic Stress. 2003;16:439-443. [pmid: 14584627].
Bryant RA, Mastrodomenico J, Felmingham KL, Hopwood S, Kenny L, Kandris E, et al. Treatment of acute stress disorder: A randomized controlled trial. Archives of General Psychiatry. 2008;65:659-667. [pmid: 18519824].
Bryant RA, Moulds ML, Guthrie RM. Acute Stress Disorder Scale: A self-report measure of acute stress disorder. Psychological Assessment. 2000;12:61-68. [pmid: 10752364].
Bryant RA, Moulds ML, Guthrie RM, Dang ST, Mastrodomenico J, Nixon RD, et al. A randomized controlled trial of exposure therapy and cognitive restructuring for posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2008;76:695-703. [pmid: 18665697].
Bryant RA, Moulds ML, Guthrie RM, Dang ST, Mastrodomenico J, Nixon RD, et al. A randomized controlled trial of exposure therapy and cognitive restructuring for posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2008;76:695-703. [pmid: 18665697].
Bryant RA, Moulds ML, Mastrodomenico J, Hopwood S, Felmingham K, Nixon RDV. Who drops out of treatment for post-traumatic stress disorder?. Clinical Psychologist. 2007;11:13-15.
Bryant-Davis T, Ocampo C. Racist incident based trauma. The Counseling Psychologist. 2005;33:479-500.
Brymer M, Jacobs A, Layne C, Pynoos R, Ruzek J, Steinberg A, et al. 2006. Appendix E: Handouts: Connecting with others: Seeking Social Support. (Rep. No. 2nd). White River Junction, VT. National Center for PTSD.
Bugg A, Turpin G, Mason S, Scholes C. A randomised controlled trial of the effectiveness of writing as a self-help intervention for traumatic injury patients at risk of developing post-traumatic stress disorder. Behaviour Research and Therapy. 2009;47:6-12. [pmid: 19012880].
Burke PA, Carruth B, Prichard D. Counselor self-care in work with traumatized addicted people. Carruth B, editor. Psychological trauma and addiction treatment. 2006:283-302. New York. Haworth Press.
Burnam MA, Meredith LS, Tanielian T, Jaycox LH. Mental health care For Iraq and Afghanistan war veterans. Health Affairs. 2009;28:771-782. [pmid: 19414886].
Byers AL, Yaffe K, Covinsky KE, Friedman MB, Bruce ML. High occurrence of mood and anxiety disorders among older adults: The National Comorbidity Survey Replication. Archives of General Psychiatry. 2010;67:489-496. [pmid: 20439830].
Byers MG, Allison KM, Wendel CS, Lee JK. Prazosin versus quetiapine for nighttime posttraumatic stress disorder symptoms in veterans: An assessment of long-term comparative effectiveness and safety. Journal of Clinical Psychopharmacology. 2010;30:225-229. [pmid: 20473055].
Cahill SP, Foa EB, Hembree EA, Marshall RD, Nacash N. Dissemination of exposure therapy in the treatment of posttraumatic stress disorder. Journal of Traumatic Stress. 2006;19:597-610. [pmid: 17075914].
Cahill SP, Rothbaum BO, Resick PA, Follette VM. Cognitive–behavioral therapy for adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:139-222. New York. Guilford Press.
Caldwell BA, Redeker N. Sleep and trauma: An overview. Issues in Mental Health Nursing. 2005;26:721-738. [pmid: 16126648].
Callcott P, Dudley R, Standart S, Freeston M, Turkington D. Treating trauma in people with first-episode psychosis using cognitive behavioural therapy. CBT for psychosis: A symptom-based approach. 2011:175-192. New York. Routledge/Taylor & Francis Group.
Campbell R, Dworkin E, Cabral G. An ecological model of the impact of sexual assault on women’s mental health. Trauma Violence Abuse. 2009;10:225-246. [pmid: 19433406].
Campbell-Sills L, Stein MB. Psychometric analysis and refinement of the Connor–Davidson Resilience Scale (CD–RISC): Validation of a 10-item measure of resilience. Journal of Traumatic Stress. 2007;20:1019-1028. [pmid: 18157881].
Cardeña E, Croyle K. 2005. Acute reactions to trauma and psychotherapy: A multidisciplinary and international perspective. Binghamton, NY. Haworth Medical Press.
Cardeña E, Carlson E. Acute stress disorder revisited. Annual Review of Clinical Psychology. 2011;7:245-267.
Cardeña E, Koopman C, Classen C, Waelde LC, Spiegel D. Psychometric properties of the Stanford Acute Stress Reaction Questionnaire (SASRQ): A valid and reliable measure of acute stress. Journal of Traumatic Stress. 2000;13:719-734. [pmid: 11109242].
Cardeña E, Maldonado JR, Hart OVD, Spiegel D. Hypnosis. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:427-457. New York. Guilford Press.
Carleton RN, Asmundson GJG. Review of cognitive–behavioral therapies for trauma. 2nd edition. Canadian Psychology/Psychologie canadienne. 2007;48:201-203.
Carleton RN, Carleton N. Review of Clinician’s guide to PTSD: A cognitive–behavioral approach. Cognitive Behaviour Therapy. 2007;36:123-124.
Carleton RN, Peluso DL, Collimore KC, Asmundson GJ. Social anxiety and posttraumatic stress symptoms: the impact of distressing social events. Journal of Anxiety Disorders. 2011;25:49-57. [pmid: 20800426].
Carlson BE. The most important things learned about violence and trauma in the past 20 years. Journal of Interpersonal Violence. 2005;20:119-126. [pmid: 15618568].
Carlson EB, Putnam FW. An update on the Dissociative Experiences Scale. Dissociation. 1993;6:16-27.
Carlson EB, Rosser-Hogan R. Cross-cultural response to trauma: A study of traumatic experiences and posttraumatic symptoms in Cambodian refugees. Journal of Traumatic Stress. 1994;7:43-58. [pmid: 8044442].
Carlson EB, Lauderdale S, Hawkins J, Sheikh JI. Posttraumatic stress and aggression among veterans in long-term care. Journal of Geriatric Psychiatry and Neurology;Journal of Geriatric Psychiatry and Neurology. 2008;21:61-71.
Carney CE, Edinger JD. 2010. Insomnia and anxiety. New York. Springer Publishing Science + Business Media.
Carroll JFX, McGinley JJ. A screening form for identifying mental health problems in alcohol/other drug dependent persons. Alcoholism Treatment Quarterly. 2001;19:33-47.
Carswell K, Blackburn P, Barker C. The relationship between trauma, post-migration problems and the psychological well-being of refugees and asylum seekers. International Journal of Social Psychiatry. 2011;57:107-119. [pmid: 21343209].
Casteel C, Martin SL, Smith JB, Gurka KK, Kupper LL. National study of physical and sexual assault among women with disabilities. Injury Prevention. 2008;14:87-90. [pmid: 18388227].
Castro CA, Engel CC Jr, Adler AB. The challenge of providing mental health prevention and early intervention in the U.S. military. Early intervention for trauma and traumatic loss. 2004:301-318. New York. Guilford Press.
Catalano S. 2012. Intimate partner violence in the US. Washington, DC. Bureau of Justice Statistics.
Catalano SM. 2004. Criminal Victimization, 2003. Washington, DC. Bureau of Justice Statistics.
Center for Mental Health Services. 1996. Responding to the needs of people with serious and persistent mental illness in times of major disaster. (Rep No SMA 96-3077). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Mental Health Services. 2002. Dealing with the effects of trauma: A self-help guide. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Mental Health Services. 2003. Center for Mental Health Services, Division of Prevention, Traumatic Stress and Special Programs, Emergency Mental Health and Traumatic Stress Services Branch: Fact sheet. Rockville, MD. Center for Mental Health Services.
Center for Mental Health Services, Substance Abuse and Mental Health Services Administration. 2005. Roadmap to seclusion and restraint free mental health services. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Improving treatment for drug-exposed infants. Treatment Improvement Protocol (TIP) Series 5. HHS Publication No. (SMA) 95–3057. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Pregnant, substance-using women. Treatment Improvement Protocol (TIP) Series 2 (HHS Publication No SMA) 93-1998. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Screening for infectious diseases among substance abusers. Treatment Improvement Protocol (TIP) Series 6 (HHS Publication No (SMA) 95-3060). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1994. Simple screening instruments for outreach for alcohol and other drug abuse and infectious diseases. (Rep No HHS Publication No (SMA) 94-2094). Rockville, MD. Center for Substance Abuse Treatment.
Center for Substance Abuse Treatment. 1995. Alcohol and other drug screening of hospitalized trauma patients. Treatment Improvement Protocol (TIP) Series 16 (HHS Publication No (SMA) 95-3041). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Combining alcohol and other drug treatment with diversion for juveniles in the justice system. Treatment Improvement Protocol (TIP) Series 21 (HHS Publication No (SMA) 95-3051). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Developing state outcomes monitoring systems for alcohol and other drug abuse treatment. Treatment Improvement Protocol (TIP) Series 14 (HHS Publication No (SMA) 95-3031). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The role and current status of patient placement criteria in the treatment of substance use disorders. Treatment Improvement Protocol (TIP) Series 13 (HHS Publication No (SMA) 95-3021). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The tuberculosis epidemic: Legal and ethical issues for alcohol and other drug abuse treatment providers. Treatment Improvement Protocol (TIP) Series 18 (HHS Publication No (SMA) 95-3047). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1996. Treatment drug courts: Integrating substance abuse treatment with legal case processing. Treatment Improvement Protocol (TIP) Series 23 (HHS Publication No (SMA) 96-3113). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. A guide to substance abuse services for primary care clinicians. (Rep. No. HHS Publication No. (SMA) 97-3139). Rockville, MD. Substance Abuse and Mental Health Administration.
Center for Substance Abuse Treatment. 1997. Substance abuse treatment and domestic violence. (Rep No HHS Publication No (SMA) 97-3163). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Comprehensive case management for substance abuse treatment. Treatment Improvement Protocol (TIP) Series 27 (HHS Publication No (SMA) 98-3222). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Continuity of offender treatment for substance use disorders from institution to community. Treatment Improvement Protocol (TIP) Series 30 (HHS Publication No (SMA) 98-3245). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Naltrexone and alcoholism treatment. Treatment Improvement Protocol (TIP) Series 28 (HHS Publication No (SMA) 98-3206). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance abuse among older adults. Treatment Improvement Protocol (TIP) Series 26 (HHS Publication No (SMA) 98-3179). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance use disorder treatment for people with physical and cognitive disabilities. Treatment Improvement Protocol (TIP) Series 29 (HHS Publication No (SMA) 98-3249). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Brief interventions and brief therapies for substance abuse. Treatment Improvement Protocol (TIP) Series 34 (HHS Publication No (SMA) 99-3353). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Cultural issues in substance abuse treatment. (Rep No HHS Publication No (SMA) 99-3278). Rockville, MD. Center for Substance Abuse Treatment.
Center for Substance Abuse Treatment. 1999. Enhancing motivation for change in substance abuse treatment. (Rep. No. HHS Publication No. (SMA) 99-3354). Rockville MD. Center for Substance Abuse Treatment.
Center for Substance Abuse Treatment. 1999. Screening and assessing adolescents for substance use disorders. (Rep No HHS Publication No (SMA) 99-3282). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment of adolescents with substance use disorders. Treatment Improvement Protocol (TIP) Series 32 (HHS Publication No (SMA) 99-3283). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment for stimulant use disorders. Treatment Improvement Protocol (TIP) Series 33 (HHS Publication No (SMA) 99-3296). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Integrating substance abuse treatment and vocational services. Treatment Improvement Protocol (TIP) Series 38 (HHS Publication No (SMA) 00-3470). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with child abuse and neglect issues. (Rep No HHS Publication No (SMA) 00-3357). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37 (HHS Publication No (SMA) 00-3459). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2001. A provider’s introduction to substance abuse treatment for lesbian, gay, bisexual, and transgender individuals. (Rep No HHS Publication No (SMA) 01-3498). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Substance abuse treatment and family therapy. Treatment Improvement Protocol (TIP) Series 39 (HHS Publication No (SMA) 04-3957). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Medication-assisted treatment for opioid addiction. Treatment Improvement Protocol (TIP) Series 43 (HHS Publication No SMA 05-4048). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for adults in the criminal justice system. Treatment Improvement Protocol (TIP) Series 44 (HHS Publication No (SMA) 05-4056). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for persons with co-occurring disorders. (Rep No Treatment Improvement Protocol (TIP) Series 42 HHS Publication No SMA 05-3992). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment: Group therapy. Treatment Improvement Protocol (TIP) Series 41 (HHS Publication No SMA 05-4056). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Detoxification and substance abuse treatment. Treatment Improvement Protocol (TIP) Series 45 (HHS Publication No SMA 06-4131). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Administrative issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 46 (HHS Publication No SMA 06-4151). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Clinical issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 47 (HHS Publication No SMA 06-4182). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2008. Managing depressive symptoms in substance abuse clients during early recovery. (Rep No Treatment Improvement Protocol (TIP) Series 48 HHS Publication No (SMA) 08-4353). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Addressing suicidal thoughts and behaviors in substance abuse treatment. (Rep No Treatment Improvement Protocol (TIP) Series 50 HHS Publication No (SMA) 09-4381). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Clinical supervision and professional development of the substance abuse counselor. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Incorporating alcohol pharmacotherapies into medical practice. Treatment Improvement Protocol (TIP) Series 49 (HHS Publication No SMA 09-4380). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Substance abuse treatment: Addressing the specific needs of women. (Rep No HHS Publication No (SMA) 09-4426). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. What are peer recovery support services?. (Rep No HHS Publication No (SMA) 09-4454). Rockville, MD. Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services.
Centers for Disease Control& Prevention. 2011. Adverse childhood experiences (ACE) study. Atlanta, GA. Centers for Disease Control and Prevention.
Centers for Disease Control & Prevention. 2012. Publications by health outcome. Atlanta, GA. Centers for Disease Control and Prevention.
Centre for Addiction and Mental Health. 2011. Are you trauma-informed?. Toronto, Ontario. Centre for Addiction and Mental Health.
Centre for Clinical Interventions. 2008. Calming technique. Northbridge, Western Australia. Centre for Clinical Interventions.
Chaikin ND, Prout MF. Treating complex trauma in women within community mental health. American Journal of Orthopsychiatry. 2004;74:160-173. [pmid: 15113245].
Chambless DL, Hollon SD. Defining empirically supported therapies. Journal of Consulting and Clinical Psychology. 1998;66:7-18. [pmid: 9489259].
Charney DS, Manji HK. Life stress, genes, and depression: Multiple pathways lead to increased risk and new opportunities for intervention. Science Signaling 2004. 2004:re5.
Chaudieu I, Norton J, Ritchie K, Birmes P, Vaiva G, Ancelin ML. Late-life health consequences of exposure to trauma in a general elderly population: The mediating role of reexperiencing posttraumatic symptoms. Journal of Clinical Psychiatry. 2011;72:929-935. [pmid: 21824455].
Chen KW, Banducci AN, Guller L, Macatee RJ, Lavelle A, Daughters SB, et al. An examination of psychiatric comorbidities as a function of gender and substance type within an inpatient substance use treatment program. Drug and Alcohol Dependence. 2011;118:92-99. [pmid: 21514751].
Chen LP, Murad MH, Paras ML, Colbenson KM, Sattler AL, Goranson EN, et al. Sexual abuse and lifetime diagnosis of psychiatric disorders: Systematic review and meta-analysis. Mayo Clinic Proceedings. 2010;85:618-629. [pmid: 20458101].
Cherpitel CJ. Alcohol and violence-related injuries in the emergency room. Recent Developments in Alcoholism. 1997;13:105-118. [pmid: 9122492].
Chessen CE, Comtois KA, Landes SJ. Untreated posttraumatic stress among persons with severe mental illness despite marked trauma and symptomatology. Psychiatric Services. 2011;62:1201-1206. [pmid: 21969647].
Cheung P. Posttraumatic stress disorder among Cambodian refugees in New Zealand. International Journal of Social Psychiatry. 1994;40:17-26. [pmid: 8005775].
Chilcoat HD, Breslau N. Investigations of causal pathways between PTSD and drug use disorders. Addictive Behaviors. 1998;23:827-840. [pmid: 9801719].
Chilcoat HD, Breslau N. Posttraumatic stress disorder and drug disorders: Testing causal pathways. Archives of General Psychiatry. 1998;55:913-917. [pmid: 9783562].
Chiu KB, deRoon-Cassini TA, Brasel KJ. Factors identifying risk for psychological distress in the civilian trauma population. Academic Emergency Medicine. 2011;18:1156-1160. [pmid: 22044521].
Choi DC, Rothbaum BO, Gerardi M, Ressler KJ. Pharmacological enhancement of behavioral therapy: focus on posttraumatic stress disorder. Current Topics in Behavioral Neurosciences. 2010;2:279-299. [pmid: 21309114].
Christensen RC, Hodgkins CC, Garces LK, Estlund KL, Miller MD, Touchton R. Homeless, mentally ill and addicted: The need for abuse and trauma services. Journal of Health Care for the Poor and Underserved. 2005;16:615-621. [pmid: 16311487].
Cicchetti D, Valentino K. An ecological–transactional perspective on child maltreatment: Failure of the average expectable environment and its influence on child development. Developmental psychopathology, Vol 3: Risk, disorder, and adaptation. 2nd ed. 2006:129-201. Hoboken, NJ. John Wiley and Sons, Inc.
Cimmarusti RA, Gamero SL. Compassionate accountability in residential care: A trauma informed model. Residential Treatment for Children & Youth. 2009;26:181-193.
Claes L, Vandereycken W, Vertommen H. Self-care versus self-harm: Piercing, tattooing, and self-injuring in eating disorders. European Eating Disorders Review. 2005;13:11-18.
Clark C, Fearday FE. 2003. Triad women’s project: Group facilitator’s manual. Tampa, FL. Louis de la Parte Florida Mental Health Institute, University of South Florida.
Clark CR, McFarlane AC, Morris P, Weber DL, Sonkkilla C, Shaw M, et al. Cerebral function in posttraumatic stress disorder during verbal working memory updating: A positron emission tomography study. Biological Psychiatry. 2003;53:474-481. [pmid: 12644352].
Clark C, Young MS, Jackson E, Graeber C, Mazelis R, Kammerer N, et al. Consumer perceptions of integrated trauma-informed services among women with co-occurring disorders. The Journal of Behavioral Health Services & Research. 2008;35:71-90. [pmid: 17647107].
Classen CC, Palesh OG, Aggarwal R. Sexual revictimization: A review of the empirical literature. Trauma, Violence, & Abuse. 2005;6:103-129.
Classen CC, Palesh OG, Cavanaugh C, Koopman C, Kaupp JW, Kraemer HC, et al. A comparison of trauma-focused and present-focused group therapy for survivors of childhood sexual abuse: A randomized controlled trial. Psychological Trauma: Theory, Research, Practice, and Policy. 2011;3:84-93.
Classen C, Koopman C, Nevill-Manning K, Spiegel D. A preliminary report comparing trauma-focused and present-focused group therapy against a wait-listed condition among childhood sexual abuse survivors with PTSD. Journal of Aggression, Maltreatment & Trauma. 2001;4:265-288.
Cloitre M. Effective psychotherapies for posttraumatic stress disorder: A review and critique. CNS Spectrums. 2009;14:32-43. [pmid: 19169192].
Cloitre M, Courtois CA, Charuvastra A, Carapezza R, Stolbach BC, Green BL. Treatment of complex PTSD: Results of the ISTSS expert clinician survey on best practices. Journal of Traumatic Stress. 2011;24:615-627. [pmid: 22147449].
Cloitre M, Koenen KC, Cohen LR, Han H. Skills training in affective and interpersonal regulation followed by exposure: A phase-based treatment for PTSD related to childhood abuse. Journal of Consulting and Clinical Psychology. 2002;70:1067-1074. [pmid: 12362957].
Cloitre M, Petkova E, Wang J, Lu LF. 2012. An examination of the influence of a sequential treatment on the course and impact of dissociation among women with PTSD related to childhood abuse. Depression and Anxiety.
Cloitre M, Stovall–McClough KC, Nooner K, Zorbas P, Cherry S, Jackson CL, et al. Treatment for PTSD related to childhood abuse: A randomized controlled trial. American Journal of Psychiatry. 2010;167:915-924. [pmid: 20595411].
Cocozza JJ, Jackson EW, Hennigan K, Morrissey JP, Reed BG, Fallot R, et al. Outcomes for women with co-occurring disorders and trauma: Program-level effects. Journal of Substance Abuse Treatment. 2005;28:109-119. [pmid: 15780540].
Coffey SF, Dansky BS, Brady KT. Exposure-based, trauma focused therapy for comorbid posttraumatic stress disorder–substance use disorder. Ouimette P, Brown PJ, editors. Trauma and Substance Abuse: Causes, Consequences, and Treatment of Comorbid Disorders. 2003:127-146. Washington, DC. American Psychological Association.
Coffey SF, Schumacher JA, Brady KT, Dansky BS. 2003. Reductions in trauma symptomalogy during acute and protracted alcohol and cocaine abstinence. Symposium Conducted at the Annual Meeting of the International Society for Traumatic Stress Studies. Chicago, IL.
Coffey SF, Schumacher JA, Brimo ML, Brady KT. Exposure therapy for substance abusers with PTSD: translating research to practice. Behavior Modification. 2005;29:10-38. [pmid: 15557477].
Cohen H, Kaplan Z, Matar MA, Loewenthal U, Zohar J, Richter-Levin G. Long–lasting behavioral effects of juvenile trauma in an animal model of PTSD associated with a failure of the autonomic nervous system to recover. European Neuropsychopharmacology. 2007;17:464-477. [pmid: 17196373].
Cohen JA, Mannarino AP, Murray LK. Trauma-focused CBT for youth who experience ongoing traumas. Child Abuse & Neglect. 2011;35:637-646. [pmid: 21855140].
Cohen LR, Hien DA. Treatment outcomes for women with substance abuse and PTSD who have experienced complex trauma. Psychiatric Services. 2006;57:100-106. [pmid: 16399969].
Cohen PF. The care and feeding of the therapist in times of trauma. Psychoanalysis & Psychotherapy. 2004;21:81-99.
Coker AL, Weston R, Creson DL, Justice B, Blakeney P. PTSD symptoms among men and women survivors of intimate partner violence: The role of risk and protective factors. Violence and Victims. 2005;20:625-643. [pmid: 16468442].
Collimore KC, Carleton RN, Hofmann SG, Asmundson GJG. Posttraumatic stress and social anxiety: The interaction of traumatic events and interpersonal fears. Depression and Anxiety. 2010;27:1017-1026. [pmid: 20721907].
Collins S, Long A. Too tired to care? The psychological effects of working with trauma. Journal of Psychiatric and Mental Health Nursing. 2003;10:17-27. [pmid: 12558918].
Collishaw S, Pickles A, Messer J, Rutter M, Shearer C, Maughan B. Resilience to adult psychopathology following childhood maltreatment: Evidence from a community sample. Child Abuse & Neglect. 2007;31:211-229. [pmid: 17399786].
Committee on Treatment of Posttraumatic Stress Disorder & Institute of Medicine. 2008. Treatment of posttraumatic stress disorder: An assessment of the evidence. The National Academies Press.
Community Connections. 2002. Trauma and abuse in the lives of homeless women and men. Washington, DC. Community Connections, U.S. Department of Housing and Urban Development.
Conners-Burrow NA, Johnson B, Whiteside-Mansell L. Maternal substance abuse and children’s exposure to violence. Journal of Pediatric Nursing. 2009;24:360-368. [pmid: 19782894].
Connor KM, Davidson JRT. Development of a new resilience scale: The Connor-Davidson Resilience Scale (CD-RISC). Depression and Anxiety. 2003;18:76-82. [pmid: 12964174].
Connors GJ, Donovan DM, DiClemente CC. 2001. Substance abuse treatment and the stages of change, selecting and planning interventions. New York. Guilford Press.
Cook A, Blaustein M, Spinazzola J, van der Kolk B. 2003. Complex trauma in children and adolescents. Los Angeles. National Child Traumatic Stress Network.
Cook A, Spinazzola J, Ford J, Lanktree C, Blaustein M, Cloitre M, et al. Complex trauma in children and adolescents. Psychiatric Annals. 2005;35:390-398.
Cook F, Ciorciari J, Varker T, Devilly GJ. Changes in long term neural connectivity following psychological trauma. Clinical Neurophysiology. 2009;120:309-314. [pmid: 19135411].
Cook JD, Bickman L. Social support and psychological symptomatology following a natural disaster. Journal of Traumatic Stress. 1990;3:541-556.
Cook JM, Niederehe G. Trauma in older adults. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:252-276. New York. Guilford Press.
Copeland LA, Zeber JE, Bingham MO, Pugh MJ, Noël PH, Schmacker ER, et al. Transition from military to VHA care: Psychiatric health services for Iraq/Afghanistan combat-wounded. Journal of Affective Disorders. 2011;130:226-230. [pmid: 21051088].
Corcoran CB, Green BL, Goodman LA, Krinsley KE. Conceptual and methodological issues in trauma history assessment. Shalev AY, Yehuda R, McFarlane AC, editors. International handbook of human response to trauma. 2000:223-232. Dordrecht, Netherlands. Kluwer Academic Publishers.
Cornelius MC, Nugent NR, Amstadter AB, Koenen KC. Genetics of post-traumatic stress disorder: Review and recommendations for genome-wide association studies. Current Psychiatry Reports. 2010;12:313-326. [pmid: 20549395].
Corry N, Pruzinsky T, Rumsey N. Quality of life and psychosocial adjustment to burn injury: Social functioning, body image, and health policy perspectives. International Review of Psychiatry. 2009;21:539-548. [pmid: 19919207].
Cottler LB, Compton WM, Mager D, Spitznagel EL, Janca A. Posttraumatic stress disorder among substance users from the general population. American Journal of Psychiatry. 1992;149:664-670. [pmid: 1575258].
Cottler LB, Nishith P, Compton WM. Gender differences in risk factors for trauma exposure and post-traumatic stress disorder among inner-city drug abusers in and out of treatment. Comprehensive Psychiatry. 2001;42:111-117. [pmid: 11244146].
Cougle JR, Feldner MT, Keough ME, Hawkins KA, Fitch KE. Comorbid panic attacks among individuals with posttraumatic stress disorder: Associations with traumatic event exposure history, symptoms, and impairment. Journal of Anxiety Disorders. 2010;24:183-188. [pmid: 19914036].
Cougle JR, Timpano KR, Sachs-Ericsson N, Keough ME, Riccardi CJ. Examining the unique relationships between anxiety disorders and childhood physical and sexual abuse in the National Comorbidity Survey–Replication. Psychiatry Research. 2010;177:150-155. [pmid: 20381878].
Coulter S. Systemic family therapy for families who have experienced trauma: A randomised controlled trial. British Journal of Social Work. 2011;41:502-519.
Courtois CA. Implications of the memory controversy for clinical practice: An overview of treatment recommendations and guidelines. Journal of Child Sexual Abuse. 2000;9:183-210. [pmid: 17521996].
Courtois CA, Ford JD, Cloitre M. Best practices in psychotherapy for adults. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:82-103. New York. Guilford Press.
Covington SS. 2003. Beyond trauma: A healing journey for women: Facilitator’s guide. Center City, Minnesota. Hazelden.
Covington SS. 2008. Helping women recover: A program for treating addiction. Revised (Loose Leaf) ed. San Francisco. Jossey-Bass.
Covington SS. Women and addiction: A trauma-informed approach. Journal of Psychoactive Drugs, Supplementement. 2008;5:377-385.
Covington SS, Burke C, Keaton S, Norcott C. Evaluation of a trauma-informed and gender-responsive intervention for women in drug treatment. Journal of Psychoactive Drugs, Supplement. 2008;5:387-398.
Craig CD, Sprang G. Compassion satisfaction, compassion fatigue, and burnout in a national sample of trauma treatment therapists. Anxiety, Stress & Coping: An International Journal. 2010;23:319-339.
Cross TL, Bazron BJ, Dennis KW, Isaacs MR. Towards a culturally competent system of care: A monograph on effective services for minority children who are severely emotionally disturbed. 1989;1. Washington, DC. Georgetown University Child Development Center.
Cubbin C, Smith GS. Socioeconomic inequalities in injury: Critical issues in design and analysis. Annual Review of Public Health. 2002;23:349-375.
Cubbin C, LeClere FB, Smith GS. Socioeconomic status and the occurrence of fatal and nonfatal injury in the United States. American Journal of Public Health. 2000;90:70-77. [pmid: 10630140].
Cukor J, Spitalnick J, Difede J, Rizzo A, Rothbaum BO. Emerging treatments for PTSD. Clinical Psychology Review. 2009;29:715-726. [pmid: 19800725].
Curie CG, Brounstein PJ, Davis NJ. Resilience-building prevention programs that work: A federal perspective. Clauss-Ehlers C, Weist M, editors. Community planning to foster resilience in children. 2004:343-359. New York. Kluwer Academic/Plenum Publishers.
Cusack KJ, Frueh BC, Brady KT. Trauma history screening in a community mental health center. Psychiatric Services. 2004;55:157-162. [pmid: 14762240].
Cusack KJ, Grubaugh AL, Yim E, Knapp RG, Robins CS, Frueh BC. Are there racial differences in the experience of harmful or traumatic events within psychiatric settings?. Psychiatric Quarterly. 2007;78:101-115. [pmid: 17345158].
Daie-Gabai A, Aderka IM, Allon–Schindel I, Foa EB, Gilboa-Schechtman E. Posttraumatic Cognitions Inventory (PTCI): Psychometric properties and gender differences in an Israeli sample. Journal of Anxiety Disorders. 2011;25:266-271. [pmid: 20971609].
Daly RJ. Samuel Pepys and post-traumatic stress disorder. British Journal of Psychiatry. 1983;143:64-68. [pmid: 6349738].
Dana RH. Refugee assessment practices and cultural competency training. Cross-cultural assessment of psychological trauma and PTSD. 2007:91-112. New York. Springer Publishing, Science + Business Media.
Danieli Y, Nader K. Respecting cultural, religious, and ethnic differences in the prevention and treatment of psychological sequelae. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:203-234. New York. Haworth Press.
Danieli Y. Assessing trauma across cultures from a multigenerational perspective. Wilson JP, Tang CS, editors. Cross-cultural assessment of psychological trauma and PTSD. 2007:65-89. New York. Springer Publishing Science + Business Media.
Danieli Y, Brom D, Sills J. Sharing knowledge and shared care. Journal of Aggression, Maltreatment & Trauma. 2005;10:775-790.
Daniels A, Grant E, Filson B, Powell I, Fricks L, Goodale L. 2010. Pillars of peer support: transforming mental health systems of care through peer support services. (Rep. No. January). Chicago. Depression and Bipolar Support Alliance.
Daniels AS, Tunner TP, Ashenden P, Bergeson S, Fricks L, Powell I. 2012. Pillars of peer support – III: Whole health peer support services. (Rep. No. January). Chicago. Depression and Bipolar Support Alliance.
Danielson CK, Amstadter AB, Dangelmaier RE, Resnick HS, Saunders BE, Kilpatrick DG. Trauma-related risk factors for substance abuse among male versus female young adults. Addict Behav. 2009;34:395-399. [pmid: 19110381].
Dannlowski U, Stuhrmann A, Beutelmann V, Zwanzger P, Lenzen T, Grotegerd D, et al. Limbic scars: Long-term consequences of childhood maltreatment revealed by functional and structural magnetic resonance imaging. Biological Psychiatry. 2012;71:286-293. [pmid: 22112927].
Dansky BS, Saladin ME, Brady KT, Kilpatrick DG, Resnick HS. Prevalence of victimization and posttraumatic stress disorder among women with substance use disorders: Comparison of telephone and in-person assessment samples. International Journal of the Addictions. 1995;30:1079-1099. [pmid: 7591350].
Dass–Brailsford P, Myrick AC. Psychological trauma and substance abuse: The need for an integrated approach. Trauma, Violence, & Abuse. 2010;11:202-213.
D’Augelli AR, Grossman AH, Starks MT. Childhood gender atypicality, victimization, and PTSD among lesbian, gay, and bisexual youth. Journal of Interpersonal Violence. 2006;21:1462-1482. [pmid: 17057162].
Davidson G, Shannon C, Mulholland C, Campbell J. A longitudinal study of the effects of childhood trauma on symptoms and functioning of people with severe mental health problems. Journal of Trauma Dissociation. 2009;10:57-68. [pmid: 19197712].
Davidson JR, Connor KM. The impairment of Presidents Pierce and Coolidge after traumatic bereavement. Comprehensive Psychiatry. 2008;49:413-419. [pmid: 18555064].
Davidson JRT, Payne VM, Connor KM, Foa EB, Rothbaum BO, Hertzberg MA, et al. Trauma, resilience and saliostasis: Effects of treatment in post-traumatic stress disorder. International Clinical Psychopharmacology. 2005;20:43-48. [pmid: 15602116].
Davidson JR, Book SW, Colket JT, Tupler LA, Roth S, David D, et al. Assessment of a new self-rating scale for post-traumatic stress disorder. Psychological Medicine. 1997;27:153-160. [pmid: 9122295].
Davidson JR, Hughes D, Blazer DG, George LK. Post-traumatic stress disorder in the community: An epidemiological study. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 1991;21:713-721.
Davidson JR, Stein DJ, Rothbaum BO, Pedersen R, Szumski A, Baldwin DS. Resilience as a predictor of treatment response in patients with posttraumatic stress disorder treated with venlafaxine extended release or placebo. Journal of Psychopharmacology. 2011;26(6):778-783. [pmid: 21926426].
Davidson PR, Parker KC. Eye movement desensitization and reprocessing (EMDR): A meta-analysis. Journal of Consulting and Clinical Psychology. 2001;69:305-316. [pmid: 11393607].
Davies DR, Burlingame GM, Layne CM. Integrating small-group process principles into trauma-focused group psychotherapy: What should a group trauma therapist know?. Schein LA, Spitz HI, Burlingame GM, Muskin PR, editors. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:385-423. New York. Haworth Press.
Davis JL, Combs-Lane AM, Smith DW. Victimization and health risk behaviors: Implications for prevention programs. Health consequences of abuse in the family: A clinical guide for evidence-based practice. 2004:179-195. Washington, DC. American Psychological Association.
Davis LL, Leon AC, Toscano R, Drebing CE, Ward LC, Parker PE, et al. A randomized controlled trial of supported employment among veterans with posttraumatic stress disorder. Psychiatric Services. 2012;63:464-470. [pmid: 22307881].
Davis MC, Luecken L, Lemery-Chalfant K. Resilience in common life: Introduction to the special issue. Journal of Personality. 2009;77:1637-1644. [pmid: 19796066].
Davis RC, Taylor BG. Does batterer treatment reduce violence? A synthesis of the literature. Women and Criminal Justice. 1999;10:69-93.
Davis RG, Ressler KJ, Schwartz AC, Stephens KJ, Bradley RG. Treatment barriers for low-income, urban African Americans with undiagnosed posttraumatic stress disorder. Journal of Traumatic Stress. 2008;21:218-222. [pmid: 18404649].
De Bellis MD. Developmental traumatology: A contributory mechanism for alcohol and substance use disorders. Psychoneuroendocrinology. 2002;27:155-170. [pmid: 11750776].
de Fabrique N, Van Hasselt VB, Vecchi GM, Romano SJ. Common variables associated with the development of Stockholm Syndrome: Some case examples. Victims & Offenders. 2007;2:91-98.
de Girolamo G. International perspectives on the treatment and prevention of posttraumatic stress disorder. Wilson JP, Beverley Raphael, editors. International handbook of traumatic stress syndrome. 1993:935-946. New York. Plenum Press.
de Snyder V, Friel S, Fotso J, Khadr Z, Meresman S, Monge P, et al. Social conditions and urban health inequities: Realities, challenges and opportunities to transform the urban landscape through research and action. Journal of Urban Health. 2011;88:1183-1193. [pmid: 21850555].
Deahl MP, Klein S, Alexander DA. The costs of conflict: Meeting the mental health needs of serving personnel and service veterans. International Review of Psychiatry. 2011;23:201-209. [pmid: 21521090].
DeBate RD, Pyle GF. The Behavioral Ecological Model: A framework for early WIC participation. American Journal of Health Studies. 2004;19:138-147.
Dedert EA, Wilson SM, Calhoun PS, Moore SD, Hamlett–Berry KW, Beckham JC. Public health clinical demonstration project for smoking cessation in veterans with posttraumatic stress disorder. Addictive Behaviors. 2010;35:19-22. [pmid: 19737675].
Deighton RM, Gurris N, Traue H. Factors affecting burnout and compassion fatigue in psychotherapists treating torture survivors: Is the therapist’s attitude to working through trauma relevant?. Journal of Traumatic Stress. 2007;20:63-75. [pmid: 17345651].
Dekel R, Goldblatt H. Is there intergenerational transmission of trauma? The case of combat veterans’ children. American Journal of Orthopsychiatry. 2008;78:281-289. [pmid: 19123747].
Dekel R, Solomon Z. Secondary traumatization among wives of war veterans with PTSD. Figley CR, Nash WP, editors. Combat stress injury: Theory, research, and management. 2007:137-157. New York. Routledge/Taylor & Francis Group.
Del Gaizo AL, Elhai JD, Weaver TL. Posttraumatic stress disorder, poor physical health and substance use behaviors in a national trauma-exposed sample. Psychiatry Research. 2011;188:390-395. [pmid: 21481478].
Delahanty DL. 2008. The psychobiology of trauma and resilience across the lifespan. Lanham, MD. Jason Aronson.
Dell’Osso L, Carmassi C, Rucci P, Capparelli A, Paggini R, Ramacciotti CE, et al. Lifetime subthreshold mania is related to suicidality in posttraumatic stress disorder. CNS Spectrums. 2009;14:262-266. [pmid: 19407725].
dePanfilis D. 2006. Child neglect: A guide for prevention, assessment, and intervention. Washington, DC. U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families Children’s Bureau, Office on Child Abuse and Neglect.
Department of Veterans Affairs & Department of Defense. 2010. VA/DoD clinical practice guideline for management of post-traumatic stress. Washington, DC. U.S. Department of Defense.
DeSilva M, Maclachlan M, Devane D, Desmond D, Gallagher P, Schnyder U, et al. Psychosocial interventions for the prevention of disability following traumatic physical injury. Cochrane Database of Systematic Reviews. 2009:CD006422. [pmid: 19821365].
Devilly GJ, Annab R. A randomised controlled trial of group debriefing. Journal of Behavior Therapy and Experimental Psychiatry. 2008;39:42-56. [pmid: 17196547].
Devilly GJ, Varker T. The effect of stressor severity on outcome following group debriefing. Behaviour Research and Therapy. 2008;46:130-136. [pmid: 18028873].
Devilly GJ, Gist R, Cotton P. Ready! Fire! Aim! The status of psychological debriefing and therapeutic interventions: In the work place and after disasters. Review of General Psychology. 2006;10:318-345.
DeViva JC, Zayfert C, Pigeon WR, Mellman TA. Treatment of residual insomnia after CBT for PTSD: Case studies. Journal of Traumatic Stress. 2005;18:155-159. [pmid: 16281208].
DeWolfe DJ. 2000. Training manual: For mental health and human service workers in major disasters. (Rep. No. ADM 90–538). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Dietz PM, Spitz AM, Anda RF, Williamson DF, McMahon PM, Santelli JS, et al. Unintended pregnancy among adult women exposed to abuse or household dysfunction during their childhood. JAMA. 1999;282:1359-1364. [pmid: 10527183].
Difede J, Malta LS, Best S, Henn–Haase C, Metzler T, Bryant R, et al. A randomized controlled clinical treatment trial for World Trade Center attack-related PTSD in disaster workers. Journal of Nervous and Mental Disease. 2007;195:861-865. [pmid: 18043528].
DiGrande L, Neria Y, Brackbill RM, Pulliam P, Galea S. Long-term posttraumatic stress symptoms among 3,271 civilian survivors of the September 11, 2001, terrorist attacks on the World Trade Center. American Journal of Epidemiology. 2011;173:271-281. [pmid: 21190987].
DiGrande L, Perrin MA, Thorpe LE, Thalji L, Murphy J, Wu D, et al. Posttraumatic stress symptoms, PTSD, and risk factors among lower Manhattan residents 2–3 years after the September 11, 2001 terrorist attacks. Journal of Traumatic Stress. 2008;21:264-273. [pmid: 18553414].
Dillon JR. Internalized homophobia, attributions of blame, and psychological distress among lesbian, gay, and bisexual trauma victims. Dissertation Abstracts International: Section B: the Sciences & Engineering. 2001;62:2054.
Dipietro F. 2006. Vicarious trauma and compassion fatigue in battered women’s advocates: A secondary prevention program. Ann Arbor, MI. ProQuest Information & Learning.
Dirkzwager AJE, Grievink L, van der Velden PG, Yzermans CJ. Risk factors for psychological and physical health problems after a man–made disaster: Prospective study. British Journal of Psychiatry. 2006;189:144-149. [pmid: 16880484].
Doctor JN, Zoellner LA, Feeny NC. Predictors of health-related quality-of-life utilities among persons with posttraumatic stress disorder. Psychiatric Services. 2011;62:272-277. [pmid: 21363898].
Dohrenwend BP, Turner JB, Turse NA, Adams BG, Koenen KC, Marshall R. The psychological risks of Vietnam for U.S. veterans: A revisit with new data and methods. Science. 2006;313:979-982. [pmid: 16917066].
Dohrenwend BP, Turner JB, Turse NA, Adams BG, Koenen KC, Marshall R. Continuing controversy over the psychological risks of Vietnam for U.S. veterans. Journal of Traumatic Stress. 2007;20:449-465. [pmid: 17721952].
Doll LS, Haas EN. 2007. Handbook of injury and violence prevention. New York. Springer Publishing.
Dom G, De WB, Hulstijn W, Sabbe B. Traumatic experiences and posttraumatic stress disorders: Differences between treatment-seeking early- and late-onset alcoholic patients. Compr Psychiatry. 2007;48:178-185. [pmid: 17292709].
Domino ME, Morrissey JP, Chung S, Nadlicki T. Changes in service use during a trauma-informed intervention for women. Women and Health. 2006;44:105-122. [pmid: 17255068].
Domino ME, Morrissey JP, Chung S, Huntington N, Larson MJ, Russell LA. Service use and costs for women with co-occurring mental and substance use disorders and a history of violence. Psychiatric Services. 2005;56:1223-1232. [pmid: 16215187].
Donovan B, Padin-Rivera E, Kowaliw S. Transcend: Initial outcomes from a posttraumatic stress disorder/substance abuse treatment program. Journal of Traumatic Stress. 2001;14:757-772. [pmid: 11776422].
Dorahy MJ, van der Hart O. Relationship between trauma and dissociation: A historical analysis. Traumatic dissociation: Neurobiology and treatment. 2007:3-30. Arlington, VA. American Psychiatric Publishing, Inc.
Dore G, Mills K, Murray R, Teesson M, Farrugia P. Post-traumatic stress disorder, depression and suicidality in inpatients with substance use disorders. Drug and Alcohol Review. 2011;31(3):294-302. [pmid: 21521385].
Dorrepaal E, Thomaes K, Smit JH, van Balkom AJ, Van DR, Veltman DJ, et al. Stabilizing group treatment for Complex Posttraumatic Stress Disorder related to childhood abuse based on psycho-education and cognitive behavioral therapy: A pilot study. Child Abuse and Neglect. 2010;34:284-288. [pmid: 20303592].
Douglas AN, Jimenez S, Lin HJ, Frisman LK. Ethnic differences in the effects of spiritual well-being on long-term psychological and behavioral outcomes within a sample of homeless women. Cultural Diversity & Ethnic Minority Psychology. 2008;14:344-352. [pmid: 18954170].
Driessen M, Schulte S, Luedecke C, Schaefer I, Sutmann F, Ohlmeier M, et al. Trauma and PTSD in patients with alcohol, drug, or dual dependence: A multi-center study. Alcoholism: Clinical & Experimental Research. 2008;32:481-488.
Drogendijk AN, Dirkzwager AJ, Grievink L, van der Velden PG, Marcelissen FG, Kleber RJ. The correspondence between persistent self-reported post-traumatic problems and general practitioners’ reports after a major disaster. Psychological Medicine. 2007;37:193-202. [pmid: 17254364].
Drogendijk AN, van der Velden PG, Kleber RJ. Acculturation and post-disaster mental health problems among affected and non-affected immigrants: A comparative study. Journal of Affective Disorders. 2012;138:485-489. [pmid: 22377513].
Drozdek B, Wilson JP. Wrestling with the ghosts from the past in exile: Assessing trauma in asylum seekers. Wilson JP, Tang CS, editors. Cross-cultural assessment of psychological trauma and PTSD. 2007:113-131. New York. Springer Publishing Science + Business Media.
Dube SR, Anda RF, Felitti VJ, Chapman DP, Williamson DF, Giles WH. Childhood abuse, household dysfunction, and the risk of attempted suicide throughout the life span: Findings from the adverse childhood experiences study. JAMA: The Journal of the American Medical Association. 2001;286:3089-3096. [pmid: 11754674].
Dube SR, Anda RF, Felitti VJ, Edwards VJ, Croft JB. Adverse childhood experiences and personal alcohol abuse as an adult. Addictive Behaviors. 2002;27:713-725. [pmid: 12201379].
Dube SR, Anda RF, Whitfield CL, Brown DW, Felitti VJ, Dong M, et al. Long-term consequences of childhood sexual abuse by gender of victim. American Journal of Preventive Medicine. 2005;28:430-438. [pmid: 15894146].
Ducharme LJ, Knudsen HK, Roman PM. Emotional exhaustion and turnover intention in human service occupations: The protective role of coworker support. Sociological Spectrum. 2008;28:81-104.
Duckworth MP, Follette VM. 2011. Retraumatization: Assessment, treatment, and prevention. New York. Brunner-Routledge.
Duffy M, Gillespie K, Clark DM. Post-traumatic stress disorder in the context of terrorism and other civil conflict in Northern Ireland: Randomised controlled trial. BMJ: British Medical Journal. 2007;334:1147.
Dulin PL, Passmore T. Avoidance of potentially traumatic stimuli mediates the relationship between accumulated lifetime trauma and late-life depression and anxiety. Journal of Traumatic Stress. 2010;23:296-299. [pmid: 20419741].
Dunlavy AC. 2010. The impact of acculturation, trauma, and post-migration stressors on the mental health of African immigrants and refugees in Sweden. Pittsburgh, PA. University of Pittsburgh.
Dunn EC, Gilman SE, Willett JB, Slopen NB, Molnar BE. 2012. The impact of exposure to interpersonal violence on gender differences in adolescent-onset major depression: Results from the National Comorbidity Survey Replication (NCS–R). Depression and Anxiety.
Dunn NJ, Rehm LP, Schillaci J, Souchek J, Mehta P, Ashton CM, et al. A randomized trial of self-management and psychoeducational group therapies for comorbid chronic posttraumatic stress disorder and depressive disorder. Journal of Traumatic Stress. 2007;20:221-237. [pmid: 17598141].
Duran B, Duran E, Brave Heart MYH. Native Americans and trauma of history. Thornton R, editor. Studying Native America: Problems and prospects. 1998:60-76. Madison, WI. University of Wisconsin Press.
Duran E, Duran B, Brave Heart MYH, Yellow Horse-Davis S. Healing the American Indian soul wound. Danieli Y, editor. International handbook of multigenerational legacies of trauma. 1998:341-354. New York. Plenum Press.
Dutton MA, Greene R. Resilience and crime victimization. Journal of Traumatic Stress. 2010;23:215-222. [pmid: 20419729].
Dyer KFW, Dorahy MJ, Hamilton G, Corry M, Shannon M, MacSherry A, et al. Anger, aggression, and self-harm in PTSD and complex PTSD. Journal of Clinical Psychology. 2009;65:1099-1114. [pmid: 19676110].
Edwards VJ, Anda RF, Felitti VJ, Dube SR. Adverse childhood experiences and health-related quality of life as an adult. Health consequences of abuse in the family: A clinical guide for evidence-based practice. 2004:81-94. Washington, DC. American Psychological Association.
Ehlers A, Clark D. Early psychological interventions for adult survivors of trauma: A review. Biological Psychiatry. 2003;53:817-826. [pmid: 12725974].
Ehlers A, Bisson J, Clark DM, Creamer M, Pilling S, Richards D, et al. Do all psychological treatments really work the same in posttraumatic stress disorder?. Clinical Psychology Review. 2010;30:269-276. [pmid: 20051310].
Ehntholt KA, Yule W. Practitioner review: Assessment and treatment of refugee children and adolescents who have experienced war-related trauma. Journal of Child Psychology and Psychiatry. 2006;47:1197-1210. [pmid: 17176375].
Eilenberg J, Fullilove MT, Goldman RG, Mellman L. Quality and use of trauma histories obtained from psychiatric outpatients through mandated inquiry. Psychiatric Services. 1996;47:165-169. [pmid: 8825253].
Eisenman DP, Meredith LS, Rhodes H, Green BL, Kaltman S, Cassells A, et al. PTSD in Latino patients: Illness beliefs, treatment preferences, and implications for care. Journal of General Internal Medicine. 2008;23:1386-1392. [pmid: 18587619].
Elbogen EB, Fuller S, Johnson SC, Brooks S, Kinneer P, Calhoun PS, et al. Improving risk assessment of violence among military veterans: An evidence-based approach for clinical decision–making. Clinical Psychology Review. 2010;30:595-607. [pmid: 20627387].
Elbogen EB, Wagner HR, Fuller SR, Calhoun PS, Kinneer PM, Beckham JC. Correlates of anger and hostility in Iraq and Afghanistan war veterans. American Journal of Psychiatry. 2010;167:1051-1058. [pmid: 20551162].
El-Gabalawy R. 2012. Association between traumatic experiences and physical health conditions in a nationally representative sample. Silver Spring MD. Anxiety and Depression Association of America.
Elhai JD, Palmieri PA. The factor structure of posttraumatic stress disorder: A literature update, critique of methodology, and agenda for future research. Journal of Anxiety Disorders. 2011;25:849-854. [pmid: 21793239].
Elhai JD, de Francisco CL, Miguel FK, Palmieri PA, Primi R, Christopher FB. Testing whether posttraumatic stress disorder and major depressive disorder are similar or unique constructs. Journal of Anxiety Disorders. 2011;25:404-410. [pmid: 21129914].
Elhai JD, Kashdan TB, Snyder JJ, North TC, Heaney CJ, Frueh BC. Symptom severity and lifetime and prospective health service use among military veterans evaluated for PTSD. Depression and Anxiety. 2007;24:178-184. [pmid: 17001627].
Elhai JD, North TC, Frueh BC. Health service use predictors among trauma survivors: A critical review. Psychological Services. 2005;2:3-19.
Elhai JD, Patrick SL, Anderson S, Simons JS, Frueh BC. Gender- and trauma-related predictors of use of mental health treatment services among primary care patients. Psychiatric Services. 2006;57:1505-1509. [pmid: 17035574].
Elklit A, Petersen T. Exposure to traumatic events among adolescents in four nations. Torture. 2008;18:2-11. [pmid: 19289877].
Elliott DE, Bjelajac P, Fallot RD, Markoff LS, Reed BG. Trauma-informed or trauma-denied: Principles and implementation of trauma-informed services for women. Journal of Community Psychology. 2005;33:461-477.
Elliott S, Latini DM, Walker LM, Wassersug R, Robinson JW. Androgen deprivation therapy for prostate cancer: Recommendations to improve patient and partner quality of life. Journal of Sexual Medicine. 2010;7:2996-3010. [pmid: 20626600].
Elwood LS, Mott J, Lohr JM, Galovski TE. Secondary trauma symptoms in clinicians: A critical review of the construct, specificity, and implications for trauma-focused treatment. Clinical Psychology Review. 2011;31:25-36. [pmid: 21130934].
EMDR Network. 2012. A brief description of EMDR therapy. Hamden, CT. EMDR Network.
Emshoff J, Blakely C, Gray D, Jakes S, Brounstein P, Coulter J, et al. An ESID case study at the federal level. American Journal of Community Psychology. 2003;32:345-357. [pmid: 14703269].
Engdahl B, Dikel TN, Eberly R, Blank A Jr. Posttraumatic stress disorder in a community group of former prisoners of war: A normative response to severe trauma. American Journal of Psychiatry. 1997;154:1576-1581. [pmid: 9356567].
Erbes CR. Couple functioning and PTSD in returning OIF soldiers: Preliminary findings from the Readiness and Resilience in National Guard Soldiers Project. Risk and resilience in US military families. 2011:47-67. New York. Springer Publishing Science + Business Media.
Ethnocultural perspectives on disaster and trauma: Foundations, issues, and applications. 2008. New York. Springer Publishing Science + Business Media.
Evans DL, Foa EB, Gur RE, Herbert H, O’Brien CP, Seligman MEP, et al. 2005. Treating and preventing adolescent mental health disorders: What we know and what we don’t know: A research agenda for improving the mental health of our youth. New York. Oxford University Press.
Evans-Campbell T. Historical trauma in American Indian/Native Alaska communities: A multilevel framework for exploring impacts on individuals, families, and communities. Journal of Interpersonal Violence. 2008;23:316-338. [pmid: 18245571].
Everall RD, Paulson BL. Burnout and secondary traumatic stress: Impact on ethical behaviour. Canadian Journal of Counselling. 2004;38:25-35.
Everly GS Jr, Phillips SB, Kane D, Feldman D. Introduction to and overview of group psychological first Aid. Brief Treatment and Crisis Intervention. 2006;6:130-136.
Everly GS Jr, Welzant V, Jacobson JM. Resistance and resilience: The final frontier in traumatic stress management. International Journal of Emergency Mental Health. 2008;10:1522-4821.
Evren C, Dalbudak E, Cetin R, Durkaya M, Evren B. Relationship of alexithymia and temperament and character dimensions with lifetime post-traumatic stress disorder in male alcohol-dependent inpatients. Psychiatry and Clinical Neurosciences. 2010;64:111-119. [pmid: 20132531].
Evren C, Sar V, Dalbudak E, Cetin R, Durkaya M, Evren B, et al. Lifetime PTSD and quality of life among alcohol-dependent men: Impact of childhood emotional abuse and dissociation. Psychiatry Research. 2011;186:85-90. [pmid: 20667600].
Fahy A. The unbearable fatigue of compassion: Notes from a substance abuse counselor who dreams of working at Starbucks. Clinical Social Work Journal. 2007;35:199-205.
Falck RS, Wang J, Siegal HA, Carlson RG. The prevalence of psychiatric disorder among a community sample of crack cocaine users: An exploratory study with practical implications. Journal of Nervous and Mental Disease. 2004;192:503-507. [pmid: 15232321].
Falender CA, Shafranske EP. 2004. Clinical supervision: A competency-based approach. 1st ed. Washington, DC. American Psychological Association.
Fallot RD, Harris M. A trauma-informed approach to screening and assessment. Harris M, Fallot RD, editors. Using trauma theory to design service systems. 2001:23-31. San Francisco. Jossey-Bass.
Fallot RD, Harris M. 2009. Creating Cultures of Trauma-Informed Care (CCTIC): A self-assessment and planning protocol. Washington, DC. Community Connections.
Fallot RD, Harris M. The Trauma Recovery and Empowerment Model (TREM): Conceptual and practical issues in a group intervention for women. Community Mental Health Journal. 2002;38:475-485. [pmid: 12474935].
Falsetti SA, Resick PA, Davis JL. Changes in religious beliefs following trauma. Journal of Traumatic Stress. 2003;16:391-398. [pmid: 12895022].
Falsetti SA, Resnick HS, Davis JL. Multiple channel exposure therapy for women with PTSD and comorbid panic attacks. Cognitive Behaviour Therapy. 2008;37:117-130. [pmid: 18470742].
Falsetti SA, Resnick HS, Resnick PA, Kilpatrick D. The Modified PTSD Symptom Scale: A brief self-report measure of posttraumatic stress disorder. Behavior Therapist. 1993;16:161-162.
Farley M, Golding JM, Young G, Mulligan M, Minkoff JR. Trauma history and relapse probability among patients seeking substance abuse treatment. Journal of Substance Abuse Treatment. 2004;27:161-167. [pmid: 15450649].
Feder A, Charney D, Collins K. Neurobiology of resilience. Southwick SM, Litz BT, Charney D, Friedman MJ, editors. Resilience and mental health: challenges across the lifespan. 2011:1-29. New York. Cambridge University Press.
Feeny NC, Foa EB. Posttraumatic Stress Disorder. Improving outcomes and preventing relapse in cognitive–behavioral therapy. 2005:174-203. New York. Guilford Press.
Feldner MT, Babson KA, Zvolensky MJ. Smoking, traumatic event exposure, and post-traumatic stress: A critical review of the empirical literature. Clinical Psychology Review. 2007;27:14-45. [pmid: 17034916].
Feldner MT, Monson CM, Friedman MJ. A critical analysis of approaches to targeted PTSD prevention: Current status and theoretically derived future directions. Behavior Modification. 2007;31:80-116. [pmid: 17179532].
Felitti VJ. The relation between adverse childhood experiences and adult health: Turning gold into lead. The Permanente Journal. 2002;6:44-47.
Felitti VJ, Anda RF, Nordenberg D, Williamson DF, Spitz AM, Edwards V, et al. Relationship of childhood abuse and household dysfunction to many of the leading causes of death in adults: The Adverse Childhood Experiences (ACE) study. American Journal of Preventive Medicine. 1998;14:245-258. [pmid: 9635069].
Felmingham KL, Bryant RA. Gender differences in the maintenance of response to cognitive behavior therapy for posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2012;80:196-200. [pmid: 22309472].
Fergusson DM, Horwood LJ, Woodward LJ. The stability of child abuse reports: A longitudinal study of the reporting behaviour of young adults. Psychological Medicine. 2000;30:529-544. [pmid: 10883709].
Ferrier-Auerbach AG, Erbes CR, Polusny MA, Rath M, Sponheim SR. Predictors of emotional distress reported by soldiers in the combat zone. Journal of Psychiatric Research. 2010;44:470-476. [pmid: 19939409].
Fetzner MG, McMillan KA, Sareen J, Asmundson GJ. What is the association between traumatic life events and alcohol abuse/dependence in people with and without PTSD? Findings from a nationally representative sample. Depression and Anxiety. 2011;28:632-638. [pmid: 21769995].
Field CA, Caetano R. Ethnic differences in intimate partner violence in the U.S. general population: The role of alcohol use and socioeconomic status. Trauma Violence Abuse. 2004;5:303-317. [pmid: 15361585].
Figley CR. Compassion fatigue: Toward a new understanding of the costs of caring. Stamm BH, editor. Secondary traumatic stress: Self-care issues for clinicians, researchers, and educators. 1995:3-28. Lutherville, MD. Sidran Press.
Figley CR. Compassion fatigue: Psychotherapists’ chronic lack of self care. Journal of Clinical Psychology. 2002;58:1433-1441. [pmid: 12412153].
Figley CR. Origins of traumatology and prospects for the future, part I. Journal of Trauma Practice. 2002;1:17-32.
Figley CR, Nash WP. 2007. Combat stress injury: Theory, research, and management. New York. Routledge.
Finkelhor D, Ormrod R, Turner H, Hamby SL. The victimization of children and youth: A comprehensive, national survey. Child Maltreatment. 2005;10:5-25. [pmid: 15611323].
Finkelhor D, Turner H, Ormrod R, Hamby SL. Violence, abuse, and crime exposure in a national sample of children and youth. Pediatrics. 2009;124:1411-1423. [pmid: 19805459].
Finkelstein N, Markoff LS. The Women Embracing Life and Living (WELL) Project: Using the relational model to develop integrated systems of care for women with alcohol/drug use and mental health disorders with histories of violence. Alcoholism Treatment Quarterly. 2004;22:63-80.
Finkelstein N, Rechberger E, Russell LA, VanDeMark NR, Noether CD, O’Keefe M, et al. Building resilience in children of mothers who have co-occurring disorders and histories of violence: Intervention model and implementation issues. The Journal of Behavioral Health Services & Research. 2005;32:141-154. [pmid: 15834264].
First MB, Spitzer RL, Gibbon M, Williams JBW. 2011. Structured clinical interview for DSM-IV-TR Axis I disorders, research version, non-patient edition (SCID–I/NP) revised November. New York. Biometrics Research, New York State Psychiatric Institute.
First MB, Spitzer RL, Gibbon M, Williams JBW. 2011. Structured clinical interview for DSM-IV-TR Axis I disorders, research version, patient edition (SCID–I/P) revised November. New York. Biometrics Research, New York State Psychiatric Institute.
Fisher J, Ogden P. Sensorimotor psychotherapy. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:312-328. New York. Guilford Press.
Fisher MH, Hodapp RM, Dykens EM. Child abuse among children with disabilities: What We know and what we need to know. Laraine MG, editor. International review of research in mental retardation. 35 ed. 2008:251-289. Academic Press.
Flannery RB Jr. The employee victim of violence: Recognizing the impact of untreated psychological trauma. American Journal of Alzheimer’s Disease. 2001;16:230-233.
Fletcher S, Creamer M, Forbes D. Preventing post traumatic stress disorder: Are drugs the answer?. Australian and New Zealand Journal of Psychiatry. 2010;44:1064-1071. [pmid: 21070102].
Foa EB. International Society For Traumatic Stress Studies. 2009. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. New York. Guilford Press.
Foa EB, Rothbaum BO. 1998. Treating the trauma of rape: Cognitive–behavioral therapy for PTSD. New York. Guilford Press.
Foa EB, Dancu CV, Hembree EA, Jaycox LH, Meadows EA, Street GP. A comparison of exposure therapy, stress inoculation training, and their combination for reducing posttraumatic stress disorder in female assault victims. Journal of Consulting and Clinical Psychology. 1999;67:194-200. [pmid: 10224729].
Foa EB, Hembree EA, Rothbaum BO. 2007. Prolonged exposure therapy for PTSD: Emotional processing of traumatic experiences: Therapist guide. Oxford University Press. New York.
Foa EB, Hembree EA, Cahill SP, Rauch SA, Riggs DS, Feeny NC, et al. Randomized trial of prolonged exposure for posttraumatic stress disorder with and without cognitive restructuring: outcome at academic and community clinics. Journal of Consulting and Clinical Psychology. 2005;73:953-964. [pmid: 16287395].
Foa EB, Keane TM, Friedman MJ. 2000. Effective treatments of PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. New York. Guilford Press.
Foa EB, Keane TM, Friedman MJ, Cohen JA. Introduction. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:1-20. New York. Guilford Press.
Foa EB, Rothbaum BO, Furr JM. Augmenting exposure therapy with other CBT procedures. Psychiatric Annals. 2003;33:47-53.
Foa EB, Rothbaum BO, Riggs DS, Murdock TB. Treatment of posttraumatic stress disorder in rape victims: A comparison between cognitive–behavioral procedures and counseling. Journal of Consulting & Clinical Psychology. 1991;59:715-723. [pmid: 1955605].
Foa EB, Stein DJ, McFarlane AC. Symptomatology and psychopathology of mental health problems after disaster. Journal of Clinical Psychiatry. Supplement 2. 2006;67:15-25. [pmid: 16602811].
Foa EB, Zoellner LA, Feeny NC. An evaluation of three brief programs for facilitating recovery after Assault. Journal of Traumatic Stress. 2006;19:29-43. [pmid: 16568461].
Focht-New G, Barol B, Clements PT, Milliken TF. Persons with developmental disability exposed to interpersonal violence and crime: Approaches for intervention. Perspectives in Psychiatric Care. 2008;44:89-98. [pmid: 18366363].
Follette VM, Iverson KM, Ford JD. Contextual behavior trauma therapy. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:264-285. New York. Guilford Press.
Fontana A, Rosenheck R. Trauma, change in strength of religious faith, and mental health service use among veterans treated for PTSD. Journal of Nervous and Mental Disease. 2004;192:579-584. [pmid: 15348973].
Fontana A, Rosenheck R. Treatment of female veterans with posttraumatic stress disorder: The role of comfort in a predominantly male environment. Psychiatric Quarterly. 2006;77:55-67. [pmid: 16397755].
Forbes D, Creamer MC, Phelps AJ, Couineau AL, Cooper JA, Bryant RA, et al. Treating adults with acute stress disorder and post-traumatic stress disorder in general practice: A clinical update. Medical Journal of Australia. 2007;187:120-123. [pmid: 17635099].
Forbes D, Lockwood E, Elhai JD, Creamer M, O’Donnell M, Bryant R, et al. An examination of the structure of posttraumatic stress disorder in relation to the anxiety and depressive disorders. Journal of Affective Disorders. 2011;132:165-172. [pmid: 21496930].
Ford JD. Treatment implications of altered affect regulation and information processing following child maltreatment. Psychiatric Annals. 2005;35:410-419.
Ford JD. Neurobiological and developmental research: Clinical implications. Treating complex traumatic stress disorders: An evidence-based guide. 2009:31-58. New York. Guilford Press.
Ford JD, Courtois CA. Defining and understanding complex trauma and complex traumatic stress disorders. Courtois CA, Ford JD, editors. Treating complex traumatic stress disorders: An evidence-based guide. 2009:13-30. New York. Guilford Press.
Ford JD, Fournier D. Psychological trauma and post-traumatic stress disorder among women in community mental health aftercare following psychiatric intensive care. Journal of Psychiatric Intensive Care. 2007;3:27-34.
Ford JD, Russo E. Trauma-focused, present-centered, emotional self-regulation approach to integrated treatment for posttraumatic stress and addiction: Trauma Adapative Recovery Group Education and Therapy (TARGET). American Journal of Psychotherapy. 2006;60:335-355. [pmid: 17340945].
Ford JD, Saltzman W. Family systems therapy. Courtois CA, Ford JD, editors. Treating complex traumatic stress disorders: An evidence-based guide. 2009:391-414. New York. Guilford Press.
Ford JD, Fallot RD, Harris M. Group therapy. Courtois CA, Ford JD, editors. Treating complex traumatic stress disorders: An evidence-based guide. 2009:415-440. New York. Guilford Press.
Ford JD, Hawke J, Alessi S, Ledgerwood D, Petry N. Psychological trauma and PTSD symptoms as predictors of substance dependence treatment outcomes. Behavior Research and Therapy. 2007;45:2417-2431.
Forde DR. Reflections on 20 years of research on violence and trauma. Journal of Interpersonal Violence. 2005;20:26-30. [pmid: 15618557].
Fortuna LR, Porche MV, Alegría M. Political violence, psychosocial trauma, and the context of mental health services use among immigrant Latinos in the United States. Ethnicity and Health. 2008;13:435-463. [pmid: 18850369].
Fortuna LR, Porche MV, Alegría M. A qualitative study of clinicians’ use of the cultural formulation model in assessing posttraumatic stress disorder. Transcult Psychiatry. 2009;46:429-450. [pmid: 19837780].
Fosha D, Paivio SC, Gleiser K, Ford JD. Experiential and emotion-focused therapy. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:286-311. New York. Guilford Press.
Foy DW, Ruzek JI, Glynn SM, Riney SJ, Gusman FD. Trauma focus group therapy for combat-related PTSD: An update. Journal of Clinical Psychology. 2002;58:907-918. [pmid: 12115714].
Foy DW, Schnurr PP, Weiss DS, Wattenberg MS, Glynn SM, Marmar CR, et al. Group psychotherapy for PTSD. Wilson JP, Friedman MJ, Lindy JD, editors. Treating psychological trauma and PTSD. 2001:183-202. New York. Guilford Press.
Frank B, Dewart T, Schmeidler J, Demirjian A. The Impact of 9/11 on New York City’s substance abuse treatment programs: A study of program administrators. Journal of Addictive Diseases. 2006;25:5-14. [pmid: 16597568].
Frankl VE. 1992. Man’s Search For Meaning: An Introduction To Logotherapy. 4th ed. Boston. Beacon Press.
Frappell-Cooke W, Gulina M, Green K, Hacker HJ, Greenberg N. Does trauma risk management reduce psychological distress in deployed troops?. Occupational Medicine. 2010;60:645-650. [pmid: 20889815].
Frazier P, Tennen H, Gavian M, Park C, Tomich P, Tashiro T. Does self-reported posttraumatic growth reflect genuine positive change?. Psychological Science. 2009;20:912-919. [pmid: 19515115].
Fredman SJ, Monson CM, Adair KC. Implementing cognitive–behavioral conjoint therapy for PTSD with the newest generation of veterans and their partners. Cognitive and Behavioral Practice. 2011;18:120-130.
Frencher SK Jr, Benedicto CM, Kendig TD, Herman D, Barlow B, Pressley JC. A comparative analysis of serious injury and illness among homeless and housed low income residents of New York City. Journal of Trauma. 2010;69:S191-S199. [pmid: 20938307].
Friborg O, Hjemdal O, Rosenvinge JH, Martinussen M. A new rating scale for adult resilience: What are the central protective resources behind healthy adjustment?. International Journal of Methods in Psychiatric Research. 2003;12:65-76. [pmid: 12830300].
Friedman MJ, Davidson JRT. Pharmacotherapy for PTSD. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:376-405. New York. Guilford Press.
Friedman MJ. Posttraumatic stress disorder among military returnees from Afghanistan and Iraq. American Journal of Psychiatry. 2006;163:586-593. [pmid: 16585431].
Friedman MJ. PTSD and other posttraumatic syndromes. McKay D, Abramowitz JS, Taylor S, Asmundson GJG, editors. Current perspectives on the anxiety disorders: Implications for DSM-V and beyond. 2009:377-409. New York. Springer Publishing Co.
Friedman MJ. PTSD and related disorders. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:1-34. Chichester, UK. John Wiley and Sons, Inc.
Friedman MJ, Cohen JA, Foa EB, Keane TM. Integration and summary. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:617-642. New York. Guilford Press.
Friedman MJ, Keane TM, Resick PA. 2007. Handbook of PTSD: Science and practice. New York. Guilford Press.
Friedman MJ, Marmar CR, Baker DG, Sikes CR, Farfel GM. Randomized, double-blind comparison of sertraline and placebo for posttraumatic stress disorder in a Department of Veterans Affairs setting. Journal of Clinical Psychiatry. 2007;68:711-720. [pmid: 17503980].
Frisman L, Ford J, Lin HJ, Mallon S, Chang R. Outcomes of trauma treatment using the TARGET model. Journal of Groups in Addiction and Recovery. 2008;3:285-303.
Fritch AM, Lynch SM. Group treatment for adult survivors of interpersonal trauma. Journal of Psychological Trauma. 2008;7:145-169.
Frueh BC, Cousins VC, Hiers TG, Cavenaugh SD, Cusack KJ, Santos AB. The need for trauma assessment and related clinical services in a state-funded mental health system. Community Mental Health Journal. 2002;38:351-356. [pmid: 12166921].
Frueh BC, Dalton ME, Johnson MR, Hiers TG, Gold PB, Magruder KM, et al. Trauma within the psychiatric setting: Conceptual framework, research directions, and policy implications. Administration and Policy in Mental Health. 2000;28:147-154. [pmid: 11194123].
Frueh BC, Grubaugh AL, Cusack KJ, Elhai JD. Disseminating evidence-based practices for adults with PTSD and severe mental illness in public-sector mental health agencies. Behavior Modification. 2009;33:66-81. [pmid: 18723837].
Frueh BC, Knapp RG, Cusack KJ, Grubaugh AL, Sauvageot JA, Cousins VC, et al. Patients’ reports of traumatic or harmful experiences within the psychiatric setting. Psychiatric Services. 2005;56:1123-1133. [pmid: 16148328].
Fullerton CS, Ursano RJ, Wang L. Acute stress disorder, posttraumatic stress disorder, and depression in disaster or rescue workers. American Journal of Psychiatry. 2004;161:1370-1376. [pmid: 15285961].
Furnham A, Petrides KV, Sisterson G, Baluch B. Repressive coping style and positive self-presentation. British Journal of Health Psychology. 2003;8:223-249. [pmid: 12804335].
Gaillot SJ. 2011. Disparities in trauma and mental health service use. Ann Arbor, MI. ProQuest Information & Learning.
Galea S, Ahern J, Resnick, Kilpatrick D, Bucuvalas M, Gold J, et al. Psychological sequelae of the September 11 terrorist attacks in New York City. New England Journal of Medicine. 2002;346:982-987. [pmid: 11919308].
Galea S, Ahern J, Tracy M, Hubbard A, Cerda M, Goldmann E, et al. Longitudinal determinants of posttraumatic stress in a population-based cohort study. Epidemiology. 2008;19:47-54. [pmid: 18091003].
Galovski T, Lyons JA. Psychological sequelae of combat violence: A review of the impact of PTSD on the veteran’s family and possible interventions. Aggression and Violent Behavior. 2004;9:477-501.
Gapen M, Cross D, Ortigo K, Graham A, Johnson E, Evces M, et al. Perceived neighborhood disorder, community cohesion, and PTSD symptoms among low-income African Americans in an urban health setting. American Journal of Orthopsychiatry. 2011;81:31-37. [pmid: 21219273].
Gardner B, Rose J, Mason O, Tyler P, Cushway D. Cognitive therapy and behavioural coping in the management of work-related stress: An intervention study. Work & Stress. 2005;19:137-152.
Garfinkel SN, Liverzon I. Neurobiology of PTSD: A review of neuroimaging. Psychiatric Annals. 2009;39:370-381.
Garner BR, Knight K, Simpson DD. Burnout among corrections-based drug treatment staff: impact of individual and organizational factors. International Journal of Offender Therapy and Comparative Criminology. 2007;51:510-522. [pmid: 17615435].
Garno JL, Goldberg JF, Ramirez PM, Ritzler BA. Impact of childhood abuse on the clinical course of bipolar disorder. British Journal of Psychiatry. 2005;186:121-125. [pmid: 15684234].
Gelkopf M, Solomon Z, Berger R, Bleich A. The mental health impact of terrorism in Israel: A repeat cross-sectional study of Arabs and Jews. Acta Psychiatrica Scandinavica. 2008;117:369-380. [pmid: 18331581].
Geller JA, Madsen LH, Ohrenstein L. Secondary trauma: A team approach. Clinical Social Work Journal. 2004;32:415-430.
Geller JL, Nicholson J, Traverso A. The victimization of women with mental illness by treaters: A historical perspective. Sexual abuse in the lives of women diagnosed with serious mental illness. 1997:139-160. Amsterdam. Harwood Academic Publishers.
Geller R, Krasner M, Korones D. Clinician self-care: The applications of mindfulness-based approaches in preventing professional burnout and compassion fatigue. The Journal of Pain & Symptom Management. 2010;39:336.
Gellis LA, Mavandadi S, Oslin DW. Functional quality of life in full versus partial posttraumatic stress disorder among veterans returning from Iraq and Afghanistan. Primary Care Companion Journal of Clinical Psychiatry. 2010;12.
Gentilello LM, Ebel BE, Wickizer TM, Salkever DS, Rivara FP. Alcohol interventions for trauma patients treated in emergency departments and hospitals: A cost benefit analysis. Annals of Surgery. 2005;241:541-550. [pmid: 15798453].
Gentilello LM, Villaveces A, Ries RR, Nason KS, Daranciang E, Donovan DM, et al. Detection of acute alcohol intoxication and chronic alcohol dependence by trauma center staff. Journal of Trauma. 1999;47:1131-1135. [pmid: 10608546].
Gentry JE, Baranowsky AB, Dunning K. The Accelerated Recovery Program (ARP) for compassion fatigue. Treating compassion fatigue. 2002:123-137. New York. Brunner-Routledge.
Geraerts E, Lindsay DS, Merckelbach H, Jelicic M, Raymaekers L, Arnold MM, et al. Cognitive mechanisms underlying recovered-memory experiences of childhood sexual abuse. Psychological Science. 2009;20:92-98. [pmid: 19037903].
Geraerts E, Schooler JW, Merckelbach H, Jelicic M, Hauer BJ, Ambadar Z. The reality of recovered memories: Corroborating continuous and discontinuous memories of childhood sexual abuse. Psychological Science. 2007;18:564-568. [pmid: 17614862].
Gerardi M, Cukor J, Difede J, Rizzo A, Rothbaum BO. Virtual reality exposure therapy for post-traumatic stress disorder and other anxiety disorders. Current Psychiatry Reports. 2010;12:298-305. [pmid: 20535592].
Gerra G, Somaini L, Zaimovic A, Gerra ML, Maremmani I, Amore M, et al. Developmental traumatic experiences, PTSD and substance abuse vulnerability: The neurobiological link. Sher L, Vilens A, editors. Neurobiology of post-traumatic stress disorder. 2010:175-200. Nova Science Publishers. Inc.
Gewirtz AH, Polusny MA, DeGarmo DS, Khaylis A, Erbes CR. Posttraumatic stress symptoms among National Guard soldiers deployed to Iraq: Associations with parenting behaviors and couple adjustment. Journal of Consulting and Clinical Psychology. 2010;78:599-610. [pmid: 20873896].
Gewirtz A, Forgatch M, Wieling E. Parenting practices as potential mechanisms for child adjustment following mass trauma. Journal of Marital and Family Therapy. 2008;34:177-192. [pmid: 18412825].
Ghafoori B, Hierholzer RW. Personality patterns among Black, White, and Hispanic combat veterans. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:12-18.
Ghafoori B, Hierholzer R, Howsepian B, Boardman A. The role of adult attachment, parental bonding, and spiritual love in the adjustment to military trauma. Journal of Trauma & Dissociation. 2008;9:85-106. [pmid: 19042311].
Gilbert R, Widom CS, Browne K, Fergusson D, Webb E, Janson S. Burden and consequences of child maltreatment in high-income countries. Lancet. 2009;373:68-81. [pmid: 19056114].
Gill DA, Picou JS. The day the water died: Cultural impacts of the Exxon Valdez oil spill. The Exxon Valdez disaster: Readings on a modern social problem. 1997:167-187.
Gill J, Vythilingam M, Page GG. Low cortisol, high DHEA, and high levels of stimulated TNF-alpha and IL–6 in women with PTSD. Journal of Traumatic Stress. 2008;21:530-539. [pmid: 19107725].
Gillespie CF, Bradley B, Mercer K, Smith AK, Conneely K, Gapen M, et al. Trauma exposure and stress-related disorders in inner city primary care patients. General Hospital Psychiatry. 2011;31:505-514. [pmid: 19892208].
Gillespie CF, Phifer J, Bradley B, Ressler KJ. Risk and resilience: Genetic and environmental influences on development of the stress response. Depression and Anxiety. 2009;26:984-992. [pmid: 19750552].
Ginzburg K, Solomon Z, Bleich A. Repressive coping style, acute stress disorder, and posttraumatic stress disorder after myocardial infarction. Psychosomatic Medicine. 2002;64:748-757. [pmid: 12271105].
Glantz MD, Anthony JC, Berglund PA, Degenhardt L, Dierker L, Kalaydjian A, et al. Mental disorders as risk factors for later substance dependence: estimates of optimal prevention and treatment benefits. Psychological Medicine. 2009;39:1365-1377. [pmid: 19046473].
Goggins K. Focus: Expanding the circle of care: What does trauma-informed care mean for family-centered care?. Cross Currents: The Journal of Addictions and Mental Health. 2011;12(3).
Gold SD, Marx BP, Soler-Baillo JM, Sloan DM. Is life stress more traumatic than traumatic stress?. Journal of Anxiety Disorders. 2005;19:687-698. [pmid: 15927781].
Gold SN, Elhai JD. 2007. Trauma and serious mental illness. Binghamton, NY. Haworth Maltreatment & Trauma Press.
Gold SN. Benefits of a contextual approach to understanding and treating complex trauma. Journal of Trauma Dissociation. 2008;9:269-292. [pmid: 19042778].
Gold SN. Contextual therapy. Courtois CA, Ford JD, editors. Treating complex traumatic stress disorders: An evidence-based guide. 2009:227-242. New York. Guilford Press.
Goldberg JF, Garno JL. Development of posttraumatic stress disorder in adult bipolar patients with histories of severe childhood abuse. Journal of Psychiatric Research. 2005;39:595-601. [pmid: 16019032].
Goldmann E, Aiello A, Uddin M, Delva J, Koenen K, Gant LM, et al. Pervasive exposure to violence and posttraumatic stress disorder in a predominantly African American urban community: The Detroit neighborhood health study. Journal of Traumatic Stress. 2011;24:747-751. [pmid: 22144187].
Goldstein RB, Compton WM, Grant BF. Antisocial behavioral syndromes and additional psychiatric comorbidity in posttraumatic stress disorder among U.S. adults: Results from Wave 2 of the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of the American Psychiatric Nurses Association. 2010;16:145-165. [pmid: 20661317].
Gone JP. A community-based treatment for Native American historical trauma: Prospects for evidence-based practice. Journal of Consulting and Clinical Psychology. 2009;77:751-762. [pmid: 19634967].
Gonzalez P, Gonzalez GM. Acculturation, optimism, and relatively fewer depression symptoms among Mexican immigrants and Mexican Americans. Psychological Reports. 2008;103:566-576. [pmid: 19102481].
Goodell J. 2003. Who’s a hero now?. Retrieved July 4, 2013, from: http://www.nytimes.com/2003/07/27/magazine/who-s-a-hero-now.html?pagewanted=all&src=pm.
Goodkind JR, Lanoue MD, Milford J. Adaptation and implementation of cognitive behavioral intervention for trauma in schools with American Indian youth. J Clin.Child Adolesc Psychol. 2010;39:858-872. [pmid: 21058132].
Goodman GS, Ghetti S, Quas JA, Edelstein RS, Alexander KW, Redlich AD, et al. A prospective study of memory for child sexual abuse: New findings relevant to the repressed-memory controversy. Psychological Science. 2003;14:113-118. [pmid: 12661671].
Goodson J, Helstrom A, Halpern JM, Ferenschak MP, Gillihan SJ, Powers MB. The treatment of posttraumatic stress disorder in U.S. combat veterans: A meta-analytic review. Psychological Reports. 2011;109:573-599. [pmid: 22238857].
Goto T, Wilson JP. A review of the history of traumatic stress studies in Japan: From traumatic neurosis to PTSD. Trauma Violence Abuse. 2003;4:195-209. [pmid: 14697122].
Govindshenoy M, Spencer N. Abuse of the disabled child: A systematic review of population-based studies. Child: Care, Health and Development. 2007;33:552-558.
Grammer GG, Moran SC. Geriatrics. Benedek DM, editor. Clinical manual for management of PTSD. 2011:371-381. Arlington, VA. American Psychiatric Publishing, Inc.
Grant BF, Chou SP, Goldstein RB, Huang B, Stinson FS, Saha TD, et al. Prevalence, correlates, disability, and comorbidity of DSM-IV borderline personality disorder: Results from the Wave 2 National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Clinical Psychiatry. 2008;69:533-545. [pmid: 18426259].
Grant BF, Stinson FS, Dawson DA, Chou SP, Dufour MC, Compton W, et al. Prevalence and co-occurrence of substance use disorders and independent mood and anxiety disorders: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Archives of General Psychiatry. 2004;61:807-816. [pmid: 15289279].
Grant BF, Stinson FS, Hasin DS, Dawson DA, Chou SP, Anderson K. Immigration and lifetime prevalence of DSM-IV Psychiatric disorders among Mexican Americans and non-Hispanic Whites in the United States: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Archives of General Psychiatry. 2004;61:1226-1233. [pmid: 15583114].
Gratz KL, Tull MT. The relationship between emotion dysregulation and deliberate self-harm among inpatients with substance use disorders. Cognitive Therapy and Research. 2010;34:544-553. [pmid: 21132101].
Gray MJ, Elhai JD, Frueh BC. Enhancing patient satisfaction and increasing treatment compliance: patient education as a fundamental component of PTSD treatment. Psychiatric Quarterly. 2004;75:321-332. [pmid: 15563050].
Gray MJ, Elhai JD, Schmidt LO. Trauma professionals’ attitudes toward and utilization of evidence-based practices. Behavior Modification. 2007;31:732-748. [pmid: 17932233].
Green BL. Trauma History Questionnaire. Stamm BH, editor. Measurement of stress, trauma, and adaptation. 1996:366-369. Lutherville, MD. Sidran Press.
Green BL, Chung JY, Daroowalla A, Kaltman S, Debenedictis C. Evaluating the cultural validity of the stressful life events screening questionnaire. Violence Against Women. 2006;12:1191-1213. [pmid: 17090693].
Green BL, Krupnick JL, Chung J, Siddique J, Krause ED, Revicki D, et al. Impact of PTSD comorbidity on one-year outcomes in a depression trial. Journal of Clinical Psychology. 2006;62:815-835. [pmid: 16703602].
Green D, Rasmussen A, Rosenfeld B. Defining torture: A review of 40 years of health science research. Journal of Traumatic Stress. 2010;23:528-531. [pmid: 20690171].
Green JG, McLaughlin KA, Berglund PA, Gruber MJ, Sampson NA, Zaslavsky AM, et al. Childhood adversities and adult psychiatric disorders in the National Comorbidity Survey Replication I: Associations with first onset of DSM-IV disorders. Archives of General Psychiatry. 2010;67:113-123. [pmid: 20124111].
Green KT, Calhoun PS, Dennis MF, Beckham JC. Exploration of the resilience construct in posttraumatic stress disorder severity and functional correlates in military combat veterans who have served since September 11, 2001. Journal of Clinical Psychiatry. 2010;71:823-830. [pmid: 20584523].
Greenberg GA, Rosenheck RA. Correlates of past homelessness in the National Epidemiological Survey on Alcohol and Related Conditions. Administration and Policy in Mental Health. 2010;37:357-366. [pmid: 19763814].
Greenberg GA, Rosenheck RA. Mental health correlates of past homelessness in the National Comorbidity Study Replication. Journal of Health Care for the Poor and Underserved. 2010;21:1234-1249. [pmid: 21099075].
Greene LR, Meisler AW, Pilkey D, Alexander G, Cardella LA, Sirois BC, et al. Psychological work with groups in the Veterans Administration. DeLucia–Waack JL, Gerrity DA, Kalodner CR, Riva MT, editors. Handbook of group counseling and psychotherapy. 2004:322-337. Thousand Oaks, CA. Sage Publications Ltd.
Grieger TA, Cozza SJ, Ursano RJ, Hoge C, Martinez PE, Engel CC, et al. Posttraumatic stress disorder and depression in battle-injured soldiers. American Journal of Psychiatry. 2006;163:1777-1783. [pmid: 17012689].
Grievink L, van der Velden PG, Stellato RK, Dusseldorp A, Gersons BP, Kleber RJ, et al. A longitudinal comparative study of the physical and mental health problems of affected residents of the firework disaster in Enschede, The Netherlands. Public Health. 2007;121:367-374. [pmid: 17320920].
Gros DF, Frueh BC, Magruder KM. Prevalence and features of panic disorder and comparison to posttraumatic stress disorder in VA primary care. General Hospital Psychiatry. 2011;33:482-488. [pmid: 21816481].
Grossman D. 1995. On killing: The psychological cost of learning to kill in war and society. 1st ed. Boston. Little Brown.
Grubaugh AL, Elhai JD, Cusack KJ, Wells C, Frueh BC. Screening for PTSD in public-sector mental health settings: The diagnostic utility of the PTSD Checklist. Depression and Anxiety. 2007;24:124-129. [pmid: 16892418].
Grubaugh AL, Magruder KM, Waldrop AE, Elhai JD, Knapp RG, Frueh BC. Subthreshold PTSD in primary care: Prevalence, psychiatric disorders, healthcare use, and functional status. Journal of Nervous & Mental Disease. 2005;193:658-664. [pmid: 16208161].
Guarino K, Soares P, Konnath K, Clervil R, Bassuk E. 2009. Trauma-informed organizational toolkit. Rockville, MD. Center for Mental Health Services, Substance Abuse and Mental Health Services Administration and The Daniels Fund, the National Child Traumatic Stress Network and the W, K Kellogg Foundation.
Guay S, Billette V, Marchand A. Exploring the links between posttraumatic stress disorder and social support: Processes and potential research avenues. Journal of Traumatic Stress. 2006;19:327-338. [pmid: 16788995].
Gureje O. Comorbidity of pain and anxiety disorders. Current Psychiatry Reports. 2008;10:318-322. [pmid: 18627670].
Gutheil TG, Brodsky A. 2008. Preventing boundary violations in clinical practice. New York. Guilford Press.
Gutner CA, Pineles SL, Griffin MG, Bauer MR, Weierich MR, Resick PA. Physiological predictors of posttraumatic stress disorder. Journal of Traumatic Stress. 2010;23:775-784. [pmid: 21171139].
Gwadz MV, Nish D, Leonard NR, Strauss SM. Gender differences in traumatic events and rates of post-traumatic stress disorder among homeless youth. Journal of Adolescence. 2007;30:117-129. [pmid: 16524623].
Haagsma JA, Polinder S, Olff M, Toet H, Bonsel GJ, van Beeck EF. Posttraumatic stress symptoms and health-related quality of life: A two year follow-up study of injury treated at the Emergency Department. BMC Psychiatry. 2012;12:1. [pmid: 22230388].
Haagsma JA, Polinder S, Toet H, Panneman M, Havelaar AH, Bonsel GJ, et al. Beyond the neglect of psychological consequences: post-traumatic stress disorder increases the non-fatal burden of injury by more than 50%. Injury Prevention. 2011;17:21-26. [pmid: 20929853].
Haasen C, Demiralay C, Reimer J. Acculturation and mental distress among Russian and Iranian migrants in Germany. European Psychiatry, 23 Supplementement. 2008;1:10-13.
Habukawa M, Maeda M, Uchimura N. Sleep disturbances in posttraumatic stress disorder. Sher L, Vilens A, editors. Neurobiology of post-traumatic stress disorder. 2010:119-135. Nova Science Publishers. Inc.
Hagenaars MA, van MA, Hoogduin KA. Reliving and disorganization in posttraumatic stress disorder and panic disorder memories. Journal of Nervous and Mental Disease. 2009;197:627-630. [pmid: 19684502].
Halcon LL, Robertson CL, Savik K, Johnson DR, Spring MA, Butcher JN, et al. Trauma and coping in Somali and Oromo refugee youth. Journal of Adolescent Health. 2004;35:17-25. [pmid: 15193570].
Hall CW, Webster RE. Traumatic symptomatology characteristics of adult children of alcoholics. Journal of Drug Education. 2002;32:195-211. [pmid: 12379051].
Halliday G. Direct psychological therapies for nightmares: A review. Clinical Psychology Review. 1987;7:501-523.
Hamblen J. 2001. PTSD in Children and Adolescents. White River Junction, VT. National Center for Post-Traumatic Stress Disorder.
Hamblen JL, Gibson LE, Mueser KT, Norris FH. Cognitive behavioral therapy for prolonged postdisaster distress. Journal of Clinical Psychology. 2006;62:1043-1052. [pmid: 16700022].
Hamblen JL, Norris FH, Pietruszkiewicz S, Gibson LE, Naturale A, Louis C. Cognitive behavioral therapy for postdisaster distress: A community based treatment program for survivors of Hurricane Katrina. Administration and Policy in Mental Health. 2009;36:206-214. [pmid: 19365725].
Hammersley P, Dias A, Todd G, Bowen-Jones K, Reilly B, Bentall RP. Childhood trauma and hallucinations in bipolar affective disorder: preliminary investigation. British Journal of Psychiatry. 2003;182:543-547. [pmid: 12777347].
Hankin CS, Skinner KM, Sullivan LM, Miller DR, Frayne S, Tripp TJ. Prevalence of depressive and alcohol abuse symptoms among women VA outpatients who report experiencing sexual assault while in the military. Journal of Traumatic Stress. 1999;12:601-612. [pmid: 10646179].
Hanson RF, Self-Brown S. Screening and assessment of crime victimization and its effects. Journal of Traumatic Stress. 2010;23:207-214. [pmid: 20336706].
Harder LH, Chen S, Baker DG, Chow B, McFall M, Saxon A, et al. The influence of posttraumatic stress disorder numbing and hyperarousal symptom clusters in the prediction of physical health status in veterans with chronic tobacco dependence and posttraumatic stress disorder. Journal of Nervous & Mental Disease. 2011;199:940-945. [pmid: 22134452].
Hardt J, Rutter M. Validity of adult retrospective reports of adverse childhood experiences: review of the evidence. Journal of Child Psychology and Psychiatry. 2004;45:260-273. [pmid: 14982240].
Harned MS, Korslund KE, Foa EB, Linehan MM. Treating PTSD in suicidal and self-injuring women with borderline personality disorder: Development and preliminary evaluation of a Dialectical Behavior Therapy Prolonged Exposure Protocol. Behaviour Research and Therapy. 2012;50:381-386. [pmid: 22503959].
Harned MS, Najavits LM, Weiss RD. Self-harm and suicidal behavior in women with comorbid PTSD and substance dependence. American Journal of Addiction. 2006;15:392-395.
Harney PA. Resilience processes in context: Contributions and implications of Bronfenbrenner’s person–process–context model. Journal of Aggression, Maltreatment & Trauma. 2007;14:73-87.
Harpaz-Rotem I, Rosenheck RA. Serving those who served: Retention of newly returning veterans from Iraq and Afghanistan in mental health treatment. Psychiatric Services. 2011;62:22-27. [pmid: 21209295].
Harper K, Richter NL, Gorey KM. Group work with female survivors of childhood sexual abuse: Evidence of poorer outcomes among those with eating disorders. Eating Behaviors. 2009;10:45-48. [pmid: 19171317].
Harris JI, Erbes CR, Engdahl BE, Thuras P, Murray-Swank N, Grace D, et al. The effectiveness of a trauma focused spiritually integrated intervention for veterans exposed to trauma. Journal of Clinical Psychology. 2011;67:425-438. [pmid: 21294116].
Harris M, Fallot RD. Designing trauma-informed addictions services. Harris M, Fallot RD, editors. Using trauma theory to design service systems. 2001:57-73. San Francisco. Jossey-Bass.
Harris M, Fallot RD. Envisioning a trauma-informed service system: A vital paradigm shift. Harris M, Fallot RD, editors. Using trauma theory to design service systems. 2001:3-22. San Francisco. Jossey-Bass.
Harris M, Fallot RD. Trauma-informed inpatient services. Harris M, Fallot RD, editors. Using trauma theory to design service systems. 2001:33-46. San Francisco. Jossey-Bass.
Harris M, Fallot RD. Using trauma theory to design service systems: New directions for mental health services. 2001;(89). San Francisco. Jossey-Bass.
Harris M. The Community Connections Trauma Work Group. 1998. Trauma recovery and empowerment: A clinician’s guide for working with women in groups. New York. Simon & Schuster.
Harris M, Fallot RD, Berley RW. Qualitative interviews on substance abuse relapse and prevention among female trauma survivors. Psychiatric Services. 2005;56:1292-1296. [pmid: 16215198].
Harris TB, Carlisle LL, Sargent J, Primm AB. Trauma and diverse child populations. Child and Adolescent Psychiatric Clinics of North America. 2010;19:869-887. [pmid: 21056351].
Harrison RL, Westwood MJ. Preventing vicarious traumatization of mental health therapists: Identifying protective practices. Psychotherapy: Theory, Research, Practice, Training. 2009;46:203-219.
Harvard School of Medicine. 2007. NCS–R Lifetime Prevalence estimates: Table 1 Lifetime prevalence of DSM-IV/WMH–CIDI disorders by sex and cohort 1 (n=9282). Cambridge, MA. Harvard University.
Harvard School of Medicine. 2007. NCS–R Twelve-month Prevalence estimates: Table 2 12-month prevalence of DSM-IV/WMH–CIDI disorders by sex and cohort 1 (n=9282). Cambridge, MA. Harvard University.
Harvey MR, Tummala-Narra P. Sources and expression of resilience in trauma survivors: Ecological theory, multicultural perspectives. Journal of Aggression, Maltreatment & Trauma. 2007;14:1-7.
Harvey MR. An ecological view of psychological trauma and trauma recovery. Journal of Traumatic Stress. 1996;9:3-23. [pmid: 8750448].
Harvey MR. Towards an ecological understanding of resilience in trauma survivors: Implications for theory, research, and practice. Journal of Aggression, Maltreatment and Trauma. 2007;14:9-32.
Harville EW, Xiong X, Smith BW, Pridjian G, Elkind-Hirsch K, Buekens P. Combined effects of Hurricane Katrina and Hurricane Gustav on the mental health of mothers of small children. Journal of Psychiatric and Mental Health Nursing. 2011;18:288-296. [pmid: 21418428].
Haskell SG, Mattocks K, Goulet JL, Krebs EE, Skanderson M, Leslie D, et al. The burden of illness in the first year home: Do male and female VA users differ in health conditions and healthcare utilization. Womens Health Issues. 2011;21:92-97. [pmid: 21185994].
Haugen PT, Evces M, Weiss DS. Treating posttraumatic stress disorder in first responders: A systematic review. Clinical Psychology Review.
Hawkins EJ, Malte CA, Imel ZE, Saxon AJ, Kivlahan DR. 2012. Prevalence and trends of benzodiazepine use among Veterans Affairs patients with posttraumatic stress disorder, 2003–2010. Drug and Alcohol Dependence.
Hawkins F, Klas L. Time management as a stressor for helping professionals: Implications for employment. Journal of Employment Counseling. 1997;34:2-6.
Hayes SC. Acceptance and commitment therapy and the new behavior therapies: Mindfulness, acceptance, and relationship. Hayes SC, Follette VM, Linehan MM, editors. Mindfulness and acceptance: Expanding the cognitive–behavioral tradition. 2004:1-29. New York. Guilford Press.
Hebert M, Bergeron M. Efficacy of a group intervention for adult women survivors of sexual abuse. Journal of Child Sexual Abuse. 2007;16:37-61. [pmid: 18032245].
Hegadoren KM, Lasiuk GC, Coupland NJ. Posttraumatic stress disorder Part III: Health effects of interpersonal violence among women. Perspectives in Psychiatric Care. 2006;42:163-173. [pmid: 16916419].
Heim C, Mletzko T, Purselle D, Musselman DL, Nemeroff CB. The dexamethasone/corticotropin–releasing factor test in men with major depression: Role of childhood trauma. Biological Psychiatry. 2008;63:398-405. [pmid: 17825799].
Heim C, Newport DJ, Mletzko T, Miller AH, Nemeroff CB. The link between childhood trauma and depression: Insights from HPA axis studies in humans. Psychoneuroendocrinology. 2008;33:693-710. [pmid: 18602762].
Helms JE, Nicolas G, Green CE. Racism and ethnoviolence as trauma: Enhancing professional training. Traumatology. 2010;16:53-62.
Helzer J, Robins L, McEvoy L. Post-traumatic stress disorder in the general population: Findings of the Epidemiologic Catchment Area survey. New England Journal of Medicine. 1987;317:1630-1634. [pmid: 3683502].
Hembree EA, Foa EB. Posttraumatic stress disorder: Psychological factors and psychosocial interventions. Journal of Clinical Psychiatry. 2000;61:33-39. [pmid: 10795607].
Hembree EA, Foa EB, Dorfan NM, Street GP, Kowalski J, Tu X. Do patients drop out prematurely from exposure therapy for PTSD?. Journal of Traumatic Stress. 2003;16:555-562. [pmid: 14690352].
Herbert JD, Forman EM. Cross-cultural perspectives on posttraumatic stress. Rosen GM, Frueh BC, editors. Clinician’s guide to posttraumatic stress disorder. 2010:235-261. Hoboken, NJ. John Wiley and Sons, Inc.
Herbert M, Bergeron M. Efficacy of a group intervention for adult women survivors of sexual abuse. Journal of Child Sexual Abuse. 2007;16:37-61.
Herek GM. Hate crimes and stigma-related experiences among sexual minority adults in the United States: Prevalence estimates from a national probability sample. Journal of Interpersonal Violence. 2009;24:54-74. [pmid: 18391058].
Herman DB, Susser ES, Struening EL, Link BL. Adverse childhood experiences: Are they risk factors for adult homelessness?. American Journal of Public Health. 1997;87:249-255. [pmid: 9103105].
Herman J. Complex PTSD: A syndrome in survivors of prolonged and repeated trauma. Journal of Traumatic Stress. 1992;5:377-391.
Herman JL. 1992. Trauma and recovery. New York. Basic Books.
Herman JL. 1997. Trauma and recovery. Rev ed. New York. Basic Books.
Hermes ED, Rosenheck RA, Desai R, Fontana AF. 2012. Recent trends in the treatment of posttraumatic stress disorder and other mental disorders in the VHA. Psychiatric Services.
Hernandez P, Gangsei D, Engstrom D. Vicarious resilience: A new concept in work with those who survive trauma. Family Process. 2007;46:229-241. [pmid: 17593887].
Herrenkohl TI, Sousa C, Tajima EA, Herrenkohl RC, Moylan CA. Intersection of child abuse and children’s exposure to domestic violence. Trauma, Violence, & Abuse. 2008;9:84-99.
Hetrick SE, Purcell R, Garner B, Parslow R. Combined pharmacotherapy and psychological therapies for post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2010:CD007316. [pmid: 20614457].
Hetzel-Riggin MD. Peritraumatic dissociation and PTSD effects on physiological response patterns in sexual assault victims. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:192-200.
Hewitt LN, Bhavsar P, Phelan HA. The secrets women keep: Intimate partner violence screening in the female trauma patient. Journal of Trauma. 2011;70:320-323. [pmid: 21307728].
Hien DA, Campbell ANC, Ruglass LM, Hu MC, Killeen T. The role of alcohol misuse in PTSD outcomes for women in community treatment: A secondary analysis of NIDA’s Women and Trauma Study. Drug and Alcohol Dependence. 2010;111:114-119. [pmid: 20537811].
Hien DA, Wells EA, Jiang H, Suarez-Morales L, Campbell AN, Cohen LR, et al. Multisite randomized trial of behavioral interventions for women with co-occurring PTSD and substance use disorders. Journal of Consulting and Clinical Psychology. 2009;77:607-619. [pmid: 19634955].
Hien D, Litt LC, Cohen LR, Miele GM, Campbell A. Moving research to practice: Three community-based examples of concurrent trauma and substance abuse treatment. Hien D, Litt LC, Cohen LR, Miele GM, Campbell A, editors. Trauma services for women in substance abuse treatment: An integrated approach. 2009:199-222. Washington, DC. American Psychological Association.
Hien D, Litt LC, Cohen LR, Miele GM, Campbell A. Ethnocultural considerations in the treatment of trauma and addictions. Trauma services for women in substance abuse treatment: An integrated approach. 2009:183-198. Washington, DC. American Psychological Association.
Hill JJ III, Mobo BH Jr, Cullen MR. Separating deployment-related traumatic brain injury and posttraumatic stress disorder in veterans: Preliminary findings from the Veterans Affairs traumatic brain injury screening program. American Journal of Physical Medicine and Rehabilitation. 2009;88:605-614. [pmid: 19620825].
Hill JM, Vernig PM, Lee JK, Brown C, Orsillo SM. The development of a brief acceptance and mindfulness-based program aimed at reducing sexual revictimization among college women with a history of childhood sexual abuse. Journal of Clinical Psychology. 2011;67:969-980. [pmid: 21544818].
Hillis SD, Anda RF, Felitti VJ, Marchbanks PA. Adverse childhood experiences and sexual risk behaviors in women: A retrospective cohort study. Family Planning Perspectives. 2001;33:206-211. [pmid: 11589541].
Hillis SD, Anda RF, Felitti VJ, Nordenberg D, Marchbanks PA. Adverse childhood experiences and sexually transmitted diseases in men and women: A retrospective study. Pediatrics. 2000;106:E11. [pmid: 10878180].
Himmelfarb N, Yaeger D, Mintz J. Posttraumatic stress disorder in female veterans with military and civilian sexual trauma. Journal of Traumatic Stress. 2006;19:837-846. [pmid: 17195980].
Hinton DE, Ba P, Peou S, Um K. Panic disorder among Cambodian refugees attending a psychiatric clinic. Prevalence and subtypes. General Hospital Psychiatry. 2000;22:437-444. [pmid: 11072060].
Hinton DE, Chau H, Nguyen L, Nguyen M, Pham T, Quinn S, et al. Panic disorder among Vietnamese refugees attending a psychiatric clinic: Prevalence and subtypes. General Hospital Psychiatry. 2001;23:337-344. [pmid: 11738465].
Hinton DE, Chhean D, Pich V, Safren SA, Hofmann SG, Pollack MH. A randomized controlled trial of cognitive–behavior therapy for Cambodian refugees with treatment-resistant PTSD and panic attacks: A cross-over design. Journal of Traumatic Stress. 2005;18:617-629. [pmid: 16382423].
Hinton DE, Hinton AL, Pich V, Loeum JR, Pollack MH. Nightmares among Cambodian refugees: The breaching of concentric ontological security. Culture, Medicine and Psychiatry. 2009;33:219-265.
Hinton DE, Hofmann SG, Orr SP, Pitman RK, Pollack MH, Pole N. A psychobiocultural model of orthostatic panic among Cambodian refugees: Flashbacks, catastrophic cognitions, and reduced orthostatic blood-pressure response. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:63-70.
Hinton DE, Hofmann SG, Pitman RK, Pollack MH, Barlow DH. The panic attack–posttraumatic stress disorder model: Applicability to orthostatic panic among Cambodian refugees. Cognitive Behaviour Therapy. 2008;37:101-116. [pmid: 18470741].
Hinton DE, Hofmann SG, Pollack MH, Otto MW. Mechanisms of efficacy of CBT for Cambodian refugees with PTSD: Improvement in emotion regulation and orthostatic blood pressure response. CNS Neuroscience & Therapeutics. 2009;15:255-263. [pmid: 19691545].
Hinton DE, Hofmann SG, Rivera E, Otto MW, Pollack MH. Culturally adapted CBT (CA–CBT) for Latino women with treatment-resistant PTSD: A pilot study comparing CA–CBT to applied muscle relaxation. Behaviour Research and Therapy. 2011;49:275-280. [pmid: 21333272].
Hinton DE, Kredlow MA, Bui E, Pollack MH, Hofmann SG. Treatment change of somatic symptoms and cultural syndromes among Cambodian refugees with PTSD. Depression and Anxiety. 2012;29:148-155.
Hinton DE, Nickerson A, Bryant RA. Worry, worry attacks, and PTSD among Cambodian refugees: A path analysis investigation. Social Science and Medicine. 2011;72:1817-1825. [pmid: 21663803].
Hinton DE, Park L, Hsia C, Hofmann S, Pollack MH. Anxiety disorder presentations in Asian populations: A review. CNS Neuroscience & Therapeutics. 2009;15:295-303. [pmid: 19691549].
Hinton DE, Pham T, Tran M, Safren SA, Otto MW, Pollack MH. CBT for Vietnamese refugees with treatment–resistant PTSD and panic attacks: A pilot study. Journal of Traumatic Stress. 2004;17:429-433. [pmid: 15633922].
Hinton DE, Pich V, Marques L, Nickerson A, Pollack MH. Khyal attacks: A key idiom of distress among traumatized Cambodia refugees. Culture, Medicine and Psychiatry. 2010;34:244-278.
Hinton DE, Rivera EI, Hofmann SG, Barlow DH, Otto MW. Adapting CBT for traumatized refugees and ethnic minority patients: Examples from culturally adapted CBT (CA–CBT). Transcultural Psychiatry. 2012;49:340-365. [pmid: 22508639].
Hiskey S, Luckie M, Davies S, Brewin CR. The emergence of posttraumatic distress in later life: A review. Journal of Geriatric Psychiatry and Neurology. 2008;21:232-241. [pmid: 19017780].
Hobfoll SE, Canetti-Nisim D, Johnson RJ, Palmieri PA, Varley JD, Galea S. The association of exposure, risk, and resiliency factors with PTSD among Jews and Arabs exposed to repeated acts of terrorism in Israel. Journal of Traumatic Stress. 2008;21:9-21. [pmid: 18302179].
Hobfoll SE, Watson P, Bell CC, Bryant RA, Brymer MJ, Friedman MJ, et al. Five essential elements of immediate and mid–term mass trauma intervention: Empirical evidence. Psychiatry. 2007;70:283-315. [pmid: 18181708].
Hodas GR. 2006. Responding to childhood trauma: The promise and practice of trauma informed care.
Hofmann SG, Smits JA. Cognitive–behavioral therapy for adult anxiety disorders: A meta-analysis of randomized placebo-controlled trials. Journal of Clinical Psychiatry. 2008;69:621-632. [pmid: 18363421].
Hoge CW. Public health strategies and treatment of service members and veterans with combat-related mental health problems. Adler AB, Bliese PD, Castro CA, editors. Deployment psychology: Evidence-based strategies to promote mental health in the military. 2011:17-34. Washington, DC. American Psychological Association.
Hoge CW, Terhakopian A, Castro CA, Messer SC, Engel CC. Association of posttraumatic stress disorder with somatic symptoms, health care visits, and absenteeism among Iraq War veterans. The American Journal of Psychiatry. 2007;164:150-153. [pmid: 17202557].
Hoge MA, Morris JA, Daniels AS, Stuart GW, Huey LY, Adams N. 2007. An action plan for behavioral health workforce development a framework for discussion. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Holbrook TL, Hoyt DB, Stein MB, Sieber WJ. Perceived threat to life predicts posttraumatic stress disorder after major trauma: Risk factors and functional outcome. Journal of Trauma. 2001;51:287-292. [pmid: 11493786].
Holbrook TL, Hoyt DB, Stein MB, Sieber WJ. Gender differences in long-term posttraumatic stress disorder outcomes after major trauma: Women are at higher risk of adverse outcomes than men. Journal of Trauma. 2002;53:882-888. [pmid: 12435938].
Hollifield M. Acupuncture for posttraumatic stress disorder: conceptual, clinical, and biological data support further research. CNS Neuroscience & Therapeutics. 2011;17:769-779. [pmid: 22070661].
Honig AL. War then and now: From surviving to thriving. International Journal of Emergency Mental Health. 2010;12:207-212. [pmid: 21473371].
Hopper EK, Bassuk EL, Olivet J. Shelter from the storm: Trauma-informed care in homelessness services settings. The Open Health Services and Policy Journal. 2010;3:80-100.
Horowitz MJ. Posttraumatic stress disorder. American Psychiatric Association Task Force on Treatments of Psychiatric Disorders. Treatments of psychiatric disorders: A task force report of the American Psychiatric Association. 1989:2065-2082. Washington, DC. American Psychiatric Association.
Horowitz M, Wilner N, Alvarez W. Impact of Event Scale: A measure of subjective stress. Psychosomatic Medicine. 1979;41:209-218. [pmid: 472086].
Hoshmand LT. Cultural–ecological perspectives on the understanding and assessment of trauma. Cross-cultural assessment of psychological trauma and PTSD. 2007:31-50. New York. Springer Publishing Science + Business Media.
Hourani L, Bender R, Weimer B, Peeler R, Bradshaw M, Lane MB, et al. 2012. Longitudinal study of resilience and mental health in marines leaving military service. Journal of Affective Disorders.
Houston JE, Shevlin M, Adamson G, Murphy J. A person-centred approach to modelling population experiences of trauma and mental illness. Social Psychiatry and Psychiatric Epidemiology. 2011;46:149-157. [pmid: 20107975].
Hovell MF, Wahlgren DR, Adams MA. The logical and empirical basis for the behavioral ecological model. DiClemente RJ, Crosby R, Kegler M, editors. Emerging theories and models in health promotion practice and research. 2009:415-449. San Francisco. Jossey-Bass Publishers.
Hovell MF, Wahlgren DR, Gehrman C. 2002. The behavioral ecological model: Integrating public health and behavioral science. DiClemente RJ, Crosby R, Kegler M, editors. Emerging theories and models in health promotion practice and research. 1st ed. San Francisco. Jossey-Bass Publishers.
Hoyt T, Yeater EA. Comparison of posttraumatic stress disorder symptom structure models in Hispanic and White college students. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:19-30.
Huang MC, Schwandt ML, Ramchandani VA, George DT, Heilig M. Impact of multiple types of childhood trauma exposure on risk of psychiatric comorbidity among alcoholic inpatients. Alcoholism, Clinical and Experimental Research. 36. 2012;(6):598-606.
Huckshorn K. 2009. Transforming cultures of care toward recovery oriented services: Guidelines toward creating a trauma informed system of care. Austin, TX. Texas Network of Youth Services.
Hughes HM, Humphrey NN, Weaver TL. Advances in Violence and Trauma. Journal of Interpersonal Violence. 2005;20:31-38. [pmid: 15618558].
Hughes KC, Shin LM. Functional neuroimaging studies of post-traumatic stress disorder. Expert Review of Neurotherapeutics. 2011;11:275-285. [pmid: 21306214].
Hughes T, McCabe SE, Wilsnack SC, West BT, Boyd CJ. Victimization and substance use disorders in a national sample of heterosexual and sexual minority women and men. Addiction. 2010;105:2130-2140. [pmid: 20840174].
Hui CH, Triandis HC. Individualism–collectivism: A study of cross-cultural researchers. Journal of Cross-Cultural Psychology. 1986;17:225-248.
Hulette AC, Kaehler LA, Freyd JJ. Intergenerational associations between trauma and dissociation. Journal of Family Violence. 2011;26:217-225.
Humphreys C. A health inequalities perspective on violence against women. Health and Social Care in the Community. 2007;15:120-127. [pmid: 17286673].
Huriwai T. Re-enculturation: Culturally congruent interventions for Maori with alcohol- and drug-use–associated problems in New Zealand. Substance Use and Misuse. 2002;37:1259-1268. [pmid: 12180565].
Hussain A, Weisaeth L, Heir T. Changes in religious beliefs and the relation of religiosity to posttraumatic stress and life satisfaction after a natural disaster. Social Psychiatry and Psychiatric Epidemiology. 2011;46:1027-1032. [pmid: 20676883].
Hussain A, Weisaeth L, Heir T. Psychiatric disorders and functional impairment among disaster victims after exposure to a natural disaster: A population based study. Journal of Affective Disorders. 2011;128:135-141. [pmid: 20619900].
Hutton D. Patterns of psychosocial coping and adaptation among riverbank erosion-induced displacees in Bangladesh: Implications for development programming. Prehospital Disaster Medicine. 2000;15:S99.
Ilgen MA, Bohnert AS, Ignacio RV, McCarthy JF, Valenstein MM, Kim HM, et al. Psychiatric diagnoses and risk of suicide in veterans. Archives of General Psychiatry. 2010;67:1152-1158. [pmid: 21041616].
Ilgen MA, Haas E, Czyz E, Webster L, Sorrell JT, Chermack S. Treating chronic pain in veterans presenting to an addictions treatment program. Cognitive and Behavioral Practice. 2011;18:149-160.
Iliffe G, Steed LG. Exploring the counselor’s experience of working with perpetrators and survivors of domestic violence. Journal of Interpersonal Violence. 2000;15:393-412.
Institute of Medicine. 2008. Treatment of posttraumatic stress disorder: An assessment of the evidence. Washington, DC. The National Academies Press.
Institute of Medicine. 2012. Treatment of posttraumatic stress disorder in military and veteran populations: Initial assessment. Washington, DC. The National Academies Press.
Institute of Medicine, Committee on Prevention of Mental Disorders Substance Abuse Among Children, National Research Council (U.S.), et al. O’Connell ME, Boat TF, Warner KE. 2009. Preventing mental, emotional, and behavioral disorders among young people progress and possibilities. Washington, DC. National Academies Press.
Institute of Medicine & National Research Council. 2007. PTSD compensation and military service. Washington, DC. The National Academies Press.
Inter-Agency Standing Committee. 2008. Mental health and psychosocial support in emergency settings. Geneva, Switzerland. World Health Organization.
Introduction to the special issue on trauma and ethnoracial diversity. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:1-3.
Ipser JC, Stein DJ. Evidence-based pharmacotherapy of post-traumatic stress disorder (PTSD). The International Journal of Neuropharmacology. 2012;15:825-840.
Isserlin L, Zerach G, Solomon Z. Acute stress responses: A review and synthesis of ASD, ASR, and CSR. American Journal of Orthopsychiatry. 2008;78:423-429. [pmid: 19123763].
Jackson C, Nissenson K, Cloitre M. Cognitive–behavioral therapy. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:243-263. New York. Guilford Press.
Jackson C, Nissenson K, Cloitre M. Treatment for complex PTSD. Sookman D, editor. Treatment resistant anxiety disorders: Resolving impasses to symptom remission. 2010:75-104. New York. Routledge/Taylor & Francis Group.
Jacobs GA, Meyer DL. Psychological first aid: Clarifying the concept. Barbanel L, Sternberg RJ, editors. Psychological interventions in times of crisis. 2006:57-71. New York. Springer Publishing.
Jainchill N, Hawke J, Yagelka J. Gender, psychopathology, and patterns of homelessness among clients in shelter-based TCs. American Journal of Drug and Alcohol Abuse. 2000;26:553-567. [pmid: 11097192].
James DJ, Glaze LE. 2006. Mental health problems of prison and jail inmates. Washington, DC. Bureau of Justice Statistics.
Jameson C. The “short step” from love to hypnosis: A reconsideration of the Stockholm syndrome. Journal for Cultural Research. 2010;14:337-355.
Jankoski JA. Is vicarious trauma the culprit? A study of child welfare professionals. Child Welfare. 2010;89:105-120. [pmid: 21877566].
Janoff-Bulman R. 1992. Shattered assumptions: Towards a new psychology of trauma. New York. Free Press.
Janssen I, Krabbendam L, Bak M, Hanssen M, Vollebergh W, de GR, et al. Childhood abuse as a risk factor for psychotic experiences. Acta Psychiatrica Scandinavica. 2004;109:38-45. [pmid: 14674957].
Jason LA, Mileviciute I, Aase DM, Stevens E, DiGangi J, Contreras R, et al. How type of treatment and presence of PTSD affect employment, self-regulation, and abstinence. North American Journal of Psychology. 2011;13:175-186. [pmid: 23357959].
Jayasinghe N, Spielman L, Cancellare D, Difede J, Klausner EJ, Giosan C. Predictors of treatment utilization in World Trade Center attack disaster workers: Role of race/ethnicity and symptom severity. International Journal of Emergency Mental Health. 2005;7:91-99. [pmid: 16107041].
Jaycox LH, Marshall GN, Schell T. Use of mental health services by men injured through community violence. Psychiatric Services. 2004;55:415-420. [pmid: 15067154].
Jaycox LH, Zoellner L, Foa EB. Cognitive–behavior therapy for PTSD in rape survivors. Journal of Clinical Psychology. 2002;58:891-906. [pmid: 12115713].
Jenkins SR, Baird S. Secondary traumatic stress and vicarious trauma: A validational study. Journal of Traumatic Stress. 2002;15:423-432. [pmid: 12392231].
Jennings A. 2004. Models for developing trauma-informed behavioral health systems and trauma-specific services. Rockville, MD. Center for Mental Health Services.
Jennings A. 2007. Blueprint for action: Building trauma-informed mental health service systems: state accomplishments, activities and resources. Alexandria, VA. National Association of State Mental Health Program Directors, (NASMHPD) and the National Technical Assistance Center for State Mental Health Planning (NTAC).
Jennings A. 2007. Criteria for building a trauma-informed mental health service system. Adapted from “Developing trauma-informed behavioral health systems”. 2003. Andrea Blanch PhD.
Jennings A. 2009. Models for developing trauma-informed behavioral health systems and trauma-specific services: 2008 update. Alexandria, VA. National Center for Trauma-Informed Care.
Jobson L, O’Kearney R. Cultural differences in personal identity in post-traumatic stress disorder. British Journal of Clinical Psychology. 2008;47:95-109. [pmid: 17708833].
Jobson L, O’Kearney RT. Impact of cultural differences in self on cognitive appraisals in posttraumatic stress disorder. Behavioural and Cognitive Psychotherapy. 2009;37:249-266. [pmid: 19405986].
Joe S, Baser RE, Breeden GK, Neighbors HW, Jackson JS. Prevalence of and risk factors for lifetime suicide attempts among blacks in the United States. JAMA. 2006;296:2112-2123. [pmid: 17077376].
Johnson DM, Zlotnick C. A cognitive–behavioral treatment for battered women with PTSD in shelters: findings from a pilot study. Journal of Traumatic Stress. 2006;19:559-564. [pmid: 16929512].
Johnson DM, Zlotnick C. Utilization of mental health treatment and other services by battered women in shelters. Psychiatric Services. 2007;58:1595-1597. [pmid: 18048563].
Johnson DM, Palmieri PA, Jackson AP, Hobfoll SE. Emotional numbing weakens abused inner-city women’s resiliency resources. Journal of Traumatic Stress. 2007;20:197-206. [pmid: 17427905].
Johnson DM, Zlotnick C, Perez S. Cognitive behavioral treatment of PTSD in residents of battered women’s shelters: results of a randomized clinical trial. Journal of Consulting and Clinical Psychology. 2011;79:542-551. [pmid: 21787052].
Johnson DR, Lahad M, Gray A. Creative therapies for adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:479-490. New York. Guilford Press.
Johnson H, Thompson A. The development and maintenance of post-traumatic stress disorder (PTSD) in civilian adult survivors of war trauma and torture: A review. Clinical Psychology Review. 2008;28:36-47. [pmid: 17383783].
Johnson H, Thompson A, Downs M. Non-Western interpreters’ experiences of trauma: The protective role of culture following exposure to oppression. Ethnicity and Health. 2009;14:407-418. [pmid: 19259848].
Johnson JL, Baldwin J, Haring RC, Wiechelt SA, Roth S, Gryczynski J, et al. Essential information for disaster management and trauma specialists working with American Indians. Marsella AJ, Johnson JL, Watson P, Gryczynski J, editors. Ethnocultural perspectives on disaster and trauma: Foundations, issues, and applications. 2008:73-113. New York. Springer Publishing Science + Business Media.
Johnson SD. Substance use, post-traumatic stress disorder and violence. Current Opinion in Psychiatry. 2008;21:242-246. [pmid: 18382221].
Johnson SD, Striley C, Cottler LB. The association of substance use disorders with trauma exposure and PTSD among African American drug users. Addictive Behaviors. 2006;31:2063-2073. [pmid: 16580784].
Johnson SM, Courtois CA. Couple therapy. Courtois CA, Ford JD, editors. Treating complex traumatic stress disorders: An evidence-based guide. 2009:371-390. New York. Guilford Press.
Johnson SM, Hunsley J, Greenberg L, Schindler D. Emotionally focused couples therapy: Status and challenges. Clinical Psychology: Science and Practice. 1999;6:67-79.
Jones BH, Knapik JJ. Physical training and exercise-related injuries. Surveillance, research and injury prevention in military populations. Sports Medicine. 1999;27:111-125. [pmid: 10091275].
Jones N, Roberts P, Greenberg N. Peer-group risk assessment: A post-traumatic management strategy for hierarchical organizations. Occupational Medicine. 2003;53:469-475. [pmid: 14581645].
Jordan BK, Schlenger WE, Hough R, Kulka RA, Weiss D, Fairbank JA, et al. Lifetime and current prevalence of specific psychiatric disorders among Vietnam veterans and controls. Archives of General Psychiatry. 1991;48:207-215. [pmid: 1996916].
Jovanovic T, Smith A, Kamkwalala A, Poole J, Samples T, Norrholm SD, et al. Physiological markers of anxiety are increased in children of abused mothers. Journal of Child Psychology and Psychiatry. 2011;52:844-852. [pmid: 21501167].
Kabat-Zinn J. 1994. Wherever you go, there you are: Mindfulness meditation in everyday life. 1st ed. New York. Hyperion.
Kabat-Zinn J, Worcester, Stress RC. University of Massachusetts Medical Center. 1990. Full catastrophe living: Using the wisdom of your body and mind to face stress, pain, and illness. New York. Delacorte Press.
Kalra H, Kamath P, Trivedi JK, Janca A. Caregiver burden in anxiety disorders. Current Opinion in Psychiatry. 2008;21:70-73. [pmid: 18281843].
Kaltman S, Green BL, Mete M, Shara N, Miranda J. Trauma, depression, and comorbid PTSD/depression in a community sample of Latina immigrants. Psychological Trauma: Theory, Research, Practice, and Policy. 2010;2:31-39.
Kang HK, Natelson BH, Mahan CM, Lee KY, Murphy FM. Post-traumatic stress disorder and chronic fatigue syndrome–like illness among Gulf War veterans: A population-based survey of 30,000 veterans. American Journal of Epidemiology. 2003;157:141-148. [pmid: 12522021].
Kang H, Dalager N, Mahan C, Ishii E. The role of sexual assault on the risk of PTSD among Gulf War veterans. Annals of Epidemiology. 2005;15:191-195. [pmid: 15723763].
Kang YS, Choi SY, Ryu E. The effectiveness of a stress coping program based on mindfulness meditation on the stress, anxiety, and depression experienced by nursing students in Korea. Nurse Education Today. 2009;29:538-543. [pmid: 19141364].
Kanter J. Compassion fatigue and secondary traumatization: A second look. Clinical Social Work Journal. 2007;35:289-293.
Kantor EM, Beckett DR. Psychological first aid. Stoddard FJ Jr, Pandya A, Katz CL, editors. Disaster psychiatry: Readiness, evaluation, and treatment. 2011:203-212. Arlington, VA. American Psychiatric Publishing, Inc.
Kar N. Cognitive behavioral therapy for the treatment of post-traumatic stress disorder: A review. Neuropsychiatric Disease and Treatment. 2011;7:167-181. [pmid: 21552319].
Karatzias T, Power K, Brown K, McGoldrick T, Begum M, Young J, et al. A controlled comparison of the effectiveness and efficiency of two psychological therapies for posttraumatic stress disorder: Eye movement desensitization and reprocessing vs. emotional freedom techniques. Journal of Nervous and Mental Disease. 2011;199:372-378. [pmid: 21629014].
Karl A, Schaefer M, Malta LS, Dorfel D, Rohleder N, Werner A. A meta-analysis of structural brain abnormalities in PTSD. Neuroscience and Biobehavioral Reviews. 2006;30:1004-1031. [pmid: 16730374].
Karney BR, Ramchand R, Osilla KC, Caldarone LB, Burns RM. 2008. Invisible wounds: Predicting the immediate and long term consequences of mental health problems in veterans of Operation Enduring Freedom and Operation Iraqi Freedom. Santa Monica, CA. The RAND, Center for Military Health Policy Research.
Karon BP, Widener AJ. Repressed memories and World War II: Lest we forget!. Professional Psychology: Research and Practice. 1997;28:338-340.
Kartha A, Brower V, Saitz R, Samet JH, Keane TM, Liebschutz J. The impact of trauma exposure and post-traumatic stress disorder on healthcare utilization among primary care patients. Medical Care. 2008;46:388-393. [pmid: 18362818].
Kashdan TB, Morina N, Priebe S. Post-traumatic stress disorder, social anxiety disorder, and depression in survivors of the Kosovo War: Experiential avoidance as a contributor to distress and quality of life. Journal of Anxiety Disorders. 2009;23:185-196. [pmid: 18676121].
Kastrup M. PTSD epidemiology with particular reference to gender. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:82-87. Chichester, UK. John Wiley and Sons, Inc.
Kataoka SH, Stein BD, Jaycox LH, Wong M, Escudero P, Tu W, et al. A school-based mental health program for traumatized Latino immigrant children. Journal of the American Academy of Child & Adolescent Psychiatry. 2003;42:311-318. [pmid: 12595784].
Kauffman J. 2002. Loss of the assumptive world: A theory of traumatic loss. New York. Brunner-Routledge.
Kawachi I, Subramanian SV. Measuring and modeling the social and geographic context of trauma: a multilevel modeling approach. Journal of Traumatic Stress. 2006;19:195-203. [pmid: 16612828].
Keane TM, Caddell JM, Taylor KL. Mississippi Scale for Combat-Related Posttraumatic Stress Disorder: Three studies in reliability and validity. Journal of Consulting & Clinical Psychology. 1988;56:85-90. [pmid: 3346454].
Keane TM, Brief DJ, Pratt EM, Miller MW. Assessment of PTSD and its comorbidities in adults. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:279-305. New York. Guilford Press.
Keane TM, Fairbank JA, Caddell JM, Zimering RT, Taylor KL, Mora CA. Clinical evaluation of a measure to assess combat exposure. Psychological Assessment. 1989;1:53-55.
Keane TM, Piwowarczyk LA. Trauma, terror, and fear: Mental health professionals respond to the impact of 9/11—An overview. Schein LA, Spitz HI, Burlingame GM, Muskin PR, editors. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:3-16. New York. Haworth Press.
Kearney DJ, McDermott K, Malte C, Martinez M, Simpson TL. Association of participation in a mindfulness program with measures of PTSD, depression and quality of life in a veteran sample. Journal of Clinical Psychology. 2012;68:101-116. [pmid: 22125187].
Keim J, Olguin DL, Marley SC, Thieman A. Trauma and burnout: Counselors in training. Compelling counseling interventions: Celebrating VISTAS’ fifth anniversary. 2008:293-303. Alexandria, VA, US. American Counseling Association. Ann Arbor, MI. Counseling Outfitters.
Keinan G, Shrira A, Shmotkin D. 2011. The association between cumulative adversity and mental health: Considering dose and primary focus of adversity. Quality of Life Research.
Keller LO, Strohschein S, Schaffer MA, Lia-Hoagberg B. Population-based public health interventions: Innovations in practice, teaching, and management, part II. Public Health Nursing. 2004;21:469-487. [pmid: 15363027].
Kelly CM, Jorm AF, Kitchener BA. Development of mental health first aid guidelines on how a member of the public can support a person affected by a traumatic event: A Delphi study. BMC Psychiatry. 2010;10:49. [pmid: 20565918].
Kelly DC, Howe–Barksdale S, Gitelson D. 2011. Treating young veterans: Promoting resilience through practice and advocacy. New York. Springer Publishing.
Kelly UA, Skelton K, Patel M, Bradley B. More than military sexual trauma: Interpersonal violence, PTSD, and mental health in women veterans. Research in Nursing and Health. 2011;34:457-467. [pmid: 21898452].
Kelly VG, Merrill GS, Shumway M, Alvidrez J, Boccellari A. Outreach, engagement, and practical assistance: Essential aspects of PTSD care for urban victims of violent crime. Trauma, Violence, and Abuse: A Review Journal. 2010;11:144-156.
Kent M, Davis MC, Stark SL, Stewart LA. A resilience-oriented treatment for posttraumatic stress disorder: Results of a preliminary randomized clinical trial. Journal of Traumatic Stress. 2011;24:591-595. [pmid: 21898603].
Kerig PK, Sink HE, Cuellar RE, Vanderzee KL, Elfstrom JL. Implementing trauma-focused CBT with fidelity and flexibility: A family case study. Journal of Clinical Child & Adolescent Psychology. 2010;39:713-722. [pmid: 20706923].
Kersting A, Reutemann M, Gast U, Ohrmann P, Suslow T, Michael N, et al. Dissociative disorders and traumatic childhood experiences in transsexuals. Journal of Nervous and Mental Disease. 2003;191:182-189. [pmid: 12637845].
Kessler RC, Merikangas KR. The National Comorbidity Survey Replication (NCS–R): Background and aims. International Journal of Methods in Psychiatric Research. 2004;13:60-68. [pmid: 15297904].
Kessler RC. Posttraumatic stress disorder: The burden to the individual and to society. Journal of Clinical Psychiatry, 61 Supplement. 2000;5:4-12.
Kessler RC, Berglund P, Demler O, Jin R, Merikangas KR, Walters EE. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Archives of General Psychiatry. 2005;62:593-602. [pmid: 15939837].
Kessler RC, Chiu WT, Demler O, Walters EE. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Archives of General Psychiatry. 2005;62:617-627. [pmid: 15939839].
Kessler RC, Cox BJ, Green JG, Ormel J, McLaughlin KA, Merikangas KR, et al. The effects of latent variables in the development of comorbidity among common mental disorders. Depression and Anxiety. 2011;28:29-39. [pmid: 21225850].
Kessler RC, Crum RM, Warner LA, Nelson CB, Schulenberg J, Anthony JC. Lifetime co-occurrence of DSM-III–R alcohol abuse and dependence with other psychiatric disorders in the National Comorbidity Survey. Archives of General Psychiatry. 1997;54:313-321. [pmid: 9107147].
Kessler RC, McGonagle KA, Zhao S, Nelson CB, Hughes M, Eshleman S, et al. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Archives of General Psychiatry. 1994;51:8-19. [pmid: 8279933].
Kessler RC, McLaughlin KA, Green JG, Gruber MJ, Sampson NA, Zaslavsky AM, et al. Childhood adversities and adult psychopathology in the WHO World Mental Health Surveys. The British Journal of Psychiatry. 2010;197:378-385. [pmid: 21037215].
Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB. Posttraumatic stress disorder in the National Comorbidity Survey. Archives of General Psychiatry. 1995;52:1048-1060. [pmid: 7492257].
Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB, Breslau NN. Epidemiological risk factors for trauma and PTSD. Yehuda R, editor. Risk Factors for PTSD. 1999:23-59. Washington, DC. American Psychiatric Press.
Khan F, Amatya B, Hoffman K. Systematic review of multidisciplinary rehabilitation in patients with multiple trauma. British Journal of Surgery. Supplement 1. 2012;99:88-96. [pmid: 22441861].
Khantzian EJ. The self-medication hypothesis of addictive disorders: Focus on heroin and cocaine dependence. American Journal of Psychiatry. 1985;142:1259-1264. [pmid: 3904487].
Khantzian EJ. The self-medication hypothesis of substance use disorders: A reconsideration and recent applications. Harvard Review of Psychiatry. 1997;4:231-244. [pmid: 9385000].
Khaylis A, Polusny MA, Erbes CR, Gewirtz A, Rath M. Posttraumatic stress, family adjustment, and treatment preferences among National Guard Soldiers deployed to OEF/OIF. Military Medicine. 2011;176:126-131. [pmid: 21366071].
Khoo A, Dent MT, Oei TPS. Group cognitive behaviour therapy for military service-related post-traumatic stress disorder: Effectiveness, sustainability and repeatability. Australian and New Zealand Journal of Psychiatry. 2011;45:663-672. [pmid: 21870924].
Kichic R, Vera M, Reyes-Rabanillo ML. Challenges in the dissemination and implementation of exposure-based CBT for the treatment of Hispanics with PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:205-207. Chichester, UK. John Wiley and Sons, Inc.
Kilcommons AM, Morrison AP. Relationships between trauma and psychosis: An exploration of cognitive and dissociative factors. Acta Psychiatrica Scandinavica. 2005;112:351-359. [pmid: 16223422].
Kilcommons AM, Morrison AP, Knight A, Lobban F. Psychotic experiences in people who have been sexually assaulted. Social Psychiatry and Psychiatric Epidemiology. 2008;43:602-611. [pmid: 18560786].
Kilpatrick DG, Acierno R, Resnick HS, Saunders BE, Best CL. A 2-year longitudinal analysis of the relationships between violent assault and substance use in women. Journal of Consulting and Clinical Psychology. 1997;65:834-847. [pmid: 9337502].
Kilpatrick DG, Veronen LJ, Resick PA. Psychological sequelae to rape: Assessment and treatment strategies. Doleys DM, Meredith RL, Ciminero AR, editors. Behavioral medicine: Assessment and treatment strategies. 1982:473-497. New York. Plenum.
Kim E. Multidimensional acculturation attitudes and depressive symptoms in Korean Americans. Issues in Mental Health Nursing. 2009;30:98-103. [pmid: 19212867].
Kim MM, Ford JD, Howard DL, Bradford DW. Assessing trauma, substance abuse, and mental health in a sample of homeless men. Health & Social Work. 2010;35:39-48. [pmid: 20218452].
Kimbrough E, Magyari T, Langenberg P, Chesney M, Berman B. Mindfulness intervention for child abuse survivors. Journal of Clinical Psychology. 2010;66:17-33. [pmid: 19998425].
Kimerling R, Baumrind N. Access to specialty mental health services among women in California. Psychiatric Services. 2005;56:729-734. [pmid: 15939951].
Kimerling R, Calhoun KS. Somatic symptoms, social support, and treatment seeking among sexual assault victims. Journal of Consulting and Clinical Psychology. 1994;62:333-340. [pmid: 8201071].
Kimerling R, Ouimette P, Weitlauf JC. Gender issues in PTSD. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:207-228. New York. Guilford Press.
Kimerling R, Street AE, Pavao J, Smith MW, Cronkite RC, Holmes TH, et al. Military-related sexual trauma among Veterans Health Administration patients returning from Afghanistan and Iraq. American Journal of Public Health. 2010;100:1409-1412. [pmid: 20558808].
King DW, King LA, Foy DW, Gudanowski DM. Prewar factors in combat-related posttraumatic stress disorder: Structural equation modeling with a national sample of female and male Vietnam veterans. Journal of Consulting and Clinical Psychology. 1996;64:520-531. [pmid: 8698946].
Kira IA. Etiology and treatment of post-cumulative traumatic stress disorders in different cultures. Traumatology. 2010;16:128-141.
Kira IA, Ahmed A, Wasim F, Mahmoud V, Colrain J, Rai D. Group therapy for refugees and torture survivors: Treatment model innovations. International Journal of Group Psychotherapy. 2012;62:69-88. [pmid: 22229369].
Kira IA, Lewandowski LA, Templin TN, Ramaswamy V, Ozkan B, Mohanesh J. The effects of post-retribution inter-group forgiveness: The case of Iraqi refugees. Peace and Conflict. 2009;15:385-413.
Kirmayer LJ. Confusion of the senses: Implications of ethnocultural variations in somatoform and dissociative disorders for PTSD. Marsella AJ, Friedman MJ, editors. Ethnocultural aspects of posttraumatic stress disorder: Issues, research, and clinical applications. 1996:131-163. Washington, DC. American Psychological Association.
Kirmayer LJ, Rousseau C, Measham T. Sociocultural considerations. Benedek DM, Wynn GH, editors. Clinical manual for management of PTSD. 2011:415-444. Arlington, VA. American Psychiatric Publishing, Inc.
Kiser LJ. Protecting children from the dangers of urban poverty. Clinical Psychology Review. 2007;27:211-225. [pmid: 16979274].
Kiser LJ, Donohue A, Hodgkinson S, Medoff D, Black MM. Strengthening family coping resources: The feasibility of a multifamily group intervention for families exposed to trauma. Journal of Traumatic Stress. 2010;23:802-806. [pmid: 21105068].
Kitayama N, Vaccarino V, Kutner M, Weiss P, Bremner JD. Magnetic resonance imaging (MRI) measurement of hippocampal volume in posttraumatic stress disorder: A meta-analysis. Journal of Affective Disorders. 2005;88:79-86. [pmid: 16033700].
Klariç M, Francciskovic T, Klariç B, Kresiç M, Grkoviç J, Lisica ID, et al. Social support and PTSD symptoms in war-traumatized women in Bosnia and Herzegovina. Psychiatria Danubina. 2008;20:466-473. [pmid: 19011587].
Klaus PA. 2007. Crime and the nation’s households, 2005. Washington, DC. U.S. Department of Justice.
Klinic Community Health Centre. 2008. Trauma-informed: The trauma toolkit: A resource for service organizations and providers to deliver services that are trauma-informed. Winnipeg, Manitoba. Klinic Community Health Centre.
Knoll J, Resnick PJ. The detection of malingered post-traumatic stress disorder. Psychiatric Clinics of North America. 2006;29:629-647. [pmid: 16904503].
Knudsen HK, Ducharme LJ, Roman PM. Counselor emotional exhaustion and turnover intention in therapeutic communities. Journal of Substance Abuse Treatment. 2006;31:173-180. [pmid: 16919745].
Koenen KC. Developmental epidemiology of PTSD: self-regulation as a central mechanism. Annals of the New York Academy of Sciences. 2006;1071:255-266. [pmid: 16891576].
Koenen KC, Moffitt TE, Caspi A, Gregory A, Harrington H, Poulton R. The developmental mental-disorder histories of adults with posttraumatic stress disorder: A prospective longitudinal birth cohort study. Journal of Abnormal Psychology. 2008;117:460-466. [pmid: 18489223].
Koenen KC, Moffitt TE, Poulton R, Martin J, Caspi A. Early childhood factors associated with the development of post-traumatic stress disorder: Results from a longitudinal birth cohort. Psychol Med. 2007;37:181-192. [pmid: 17052377].
Koenen KC, Nugent NR, Amstadter AB. Gene–environment interaction in posttraumatic stress disorder: Review, strategy and new directions for future research. European Archives of Psychiatry and Clinical Neuroscience. 2008;258:82-96. [pmid: 18297420].
Koenen KC, Stellman JM, Stellman SD, Sommer JF Jr. Risk factors for course of posttraumatic stress disorder among Vietnam veterans: A 14-year follow-up of American Legionnaires. Journal of Consulting & Clinical Psychology. 2003;71:980-986. [pmid: 14622073].
Koenen KC, Stellman SD, Sommer JF Jr, Stellman JM. Persisting posttraumatic stress disorder symptoms and their relationship to functioning in Vietnam veterans: A 14-year follow–up. Journal of Traumatic Stress. 2008;21:49-57. [pmid: 18302174].
Kohrt BA, Hruschka DJ. Nepali concepts of psychological trauma: The role of idioms of distress, ethnopsychology and ethnophysiology in alleviating suffering and preventing stigma. Culture, Medicine and Psychiatry. 2010;34:322-352.
Kolassa IT, Eckart C, Ruf M, Neuner F, de Quervain DJF, Elbert T. Lack of cortisol response in patients with posttraumatic stress disorder (PTSD) undergoing a diagnostic interview. BMC Psychiatry. 2007;7.
Kornør H, Winje D, Ekeberg Ÿ, Weisaeth L, Kirkehei I, Johansen K, et al. Early trauma-focused cognitive–behavioural therapy to prevent chronic post-traumatic stress disorder and related symptoms: A systematic review and meta-analysis. BMC Psychiatry. 2008;8.
Koss MP. Empirically enhanced reflections on 20 years of rape research. Journal of Interpersonal Violence. 2005;20:100-107. [pmid: 15618566].
Kozaric-Kovacic D, Ljubin T, Grappe M. Comorbidity of posttraumatic stress disorder and alcohol dependence in displaced persons. Croatian Medical Journal. 2000;41:173-178. [pmid: 10853047].
Kramer TL, Green BL. Post-traumatic stress disorder: A historical context and evolution. Halpern DF, editor. States of mind: American and post-Soviet perspectives on contemporary issues in psychology. 1997:215-237. New York. Oxford University Press.
Krause ED, Kaltman S, Goodman LA, Dutton MA. Avoidant coping and PTSD symptoms related to domestic violence exposure: A longitudinal study. Journal of Traumatic Stress. 2008;21:83-90. [pmid: 18302182].
Kreidler M, Einsporn R. A comparative study of therapy duration for survivors of childhood sexual abuse. Journal of Psychosocial Nursing and Mental Health Services. 2012;50:26-32. [pmid: 22421008].
Kremen WS, Koenen KC, Boake C, Purcell S, Eisen SA, Franz CE, et al. Pretrauma cognitive ability and risk for posttraumatic stress disorder: A twin study. Archives of General Psychiatry. 2007;64:361-368. [pmid: 17339525].
Kress VE, Hoffman RM. Non-suicidal self-injury and motivational interviewing: Enhancing readiness for change. Journal of Mental Health Counseling. 2008;30:311-329.
Krieger N. 2011. Epidemiology and the people’s health: Theory and context. New York. Oxford University Press.
Kroes MC, Rugg MD, Whalley MG, Brewin CR. Structural brain abnormalities common to posttraumatic stress disorder and depression. Journal of Psychiatry and Neuroscience. 2011;36:256-265. [pmid: 21418787].
Krupnick JL, Green BL, Stockton P, Miranda J, Krause E, Mete M. Group interpersonal psychotherapy for low-income women with posttraumatic stress disorder. Psychother Res. 2008;18:497-507. [pmid: 18816001].
Krysinska K, Lester D. Post-traumatic stress disorder and suicide risk: A systematic review. Archives of Suicide Research. 2010;14:1-23. [pmid: 20112140].
Krysinska K, Lester D, Martin G. Suicidal behavior after a traumatic event. Journal of Trauma Nursing. 2009;16:103-110. [pmid: 19543020].
Kubany ES, Haynes SN, Leisen MB, Owens JA, Kaplan AS, Watson SB, et al. Development and preliminary validation of a brief broad-spectrum measure of trauma exposure: The Traumatic Life Events Questionnaire. Psychological Assessment. 2000;12:210-224. [pmid: 10887767].
Kubany ES, Hill EE, Owens JA, Iannce–Spencer C, McCaig MA, Tremayne KJ, et al. Cognitive trauma therapy for battered women with PTSD (CTT–BW). Journal of Consulting and Clinical Psychology. 2004;72:3-18. [pmid: 14756610].
Kubany ES, Leisen MB, Kaplan AS, Kelly MP. Validation of a brief measure of posttraumatic stress disorder: The distressing event questionnaire (DEQ). Psychological Assessment. 2000;12:197-209. [pmid: 10887766].
Kubzansky LD, Koenen KC, Spiro III A, Vokonas PS, Sparrow D. Perspective study of posttraumatic stress disorder symptoms and coronary heart disease in the normative aging study. Archives of General Psychiatry. 2007;64:109-116. [pmid: 17199060].
Kudler HS, Krupnick JL, Blank AS Jr, Herman JL, Horowitz MJ. Psychodynamic therapy for adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:346-369. New York. Guilford Press.
Kuhn JH, Nakashima J. 2011. Community Homelessness Assessment, Local Education and Networking Group (CHALENG) for veterans: The fifteenth annual progress report on public law 105–114 services for homeless veterans assessment and coordination, March 11, 2009. Washington, DC. Department of Veterans Affairs.
Kulka RA, Schlenger WE, Fairbank JA, Hough RL, Jordan BK, Marmar CR. 1990. The National Vietnam Veterans Readjustment Study: Tables of findings and technical appendices. Research Triangle Park, NC. Research Triangle Institute.
Kulka RA, Schlenger WE, Fairbank JA, Hough RL, Jordan BK, Marmar CR, et al. 1990. Trauma and the Vietnam war generation: Report of findings from the National Vietnam Veterans Readjustment Study. New York. Brunner/Mazel.
Kun P, Han S, Chen X, Yao L. Prevalence and risk factors for posttraumatic stress disorder: A cross-sectional study among survivors of the Wenchuan 2008 earthquake in China. Depression and Anxiety. 2009;26:1134-1140. [pmid: 19842170].
Kushner MG, Krueger R, Frye B, Peterson J. Epidemiological perspectives on co-occurring anxiety disorder and substance use disorder. Stewart SH, Conrod PJ, editors. Anxiety and substance use disorders: The vicious cycle of comorbidity. 2008:3-17. New York. Springer Publishing Science + Business Media.
Kutter CJ, Wolf EJ, McKeever VM. Predictors of veterans’ participation in cognitive–behavioral group treatment for PTSD. Journal of Traumatic Stress. 2004;17:157-162. [pmid: 15141789].
Kuzma JM, Black DW. Integrating pharmacotherapy and psychotherapy in the management of anxiety disorders. Current Psychiatry Reports. 2004;6:268-273. [pmid: 15260942].
Laban CJ, Gernaat HBPE, Komproe IH, van der Tweel I, de Jong JTVM. Postmigration living problems and common psychiatric disorders in Iraqi asylum seekers in the Netherlands. Journal of Nervous and Mental Disease. 2005;193:825-832. [pmid: 16319706].
Laban CJ, Komproe IH, Gernaat HBPE, De Jong TVM. The impact of a long asylum procedure on quality of life, disability and physical health in Iraqi asylum seekers in the Netherlands. Social Psychiatry and Psychiatric Epidemiology. 2008;43:507-515. [pmid: 18560785].
Labrie V, Roder JC. The role of NMDA receptors in the pathophysiology and treatment of anxiety syndromes. Sher L, Vilens A, editors. Neurobiology of post-traumatic stress disorder. 2010:291-308. Nova Science Publishers, Inc.
Lacoursiere RB. “Burnout” and substance user treatment: The phenomenon and the administrator–clinician’s experience”. Substance Use & Misuse. 2001;36:1839-1874. [pmid: 11795582].
Laflamme L, Burrows S, Hasselberg M. 2009. Socioeconomic differences in injury risks: A review of findings and a discussion of potential countermeasures. Denmark. World Health Organization.
Lalor K, McElvaney R. Child sexual abuse, links to later sexual exploitation/high-risk sexual behavior, and prevention/treatment programs. Trauma, Violence, & Abuse. 2010;11:159-177.
Landau J. Communities that care for families: The LINC Model for enhancing individual, family, and community resilience. American Journal of Orthopsychiatry. 2010;80:516-524. [pmid: 20950292].
Landau J, Mittal M, Wieling E. Linking human systems: Strengthening individuals, families, and communities in the wake of mass trauma. Journal of Marital and Family Therapy. 2008;34:193-209. [pmid: 18412826].
Landre L, Destrieux C, Baudry M, Barantin L, Cottier JP, Martineau J, et al. Preserved subcortical volumes and cortical thickness in women with sexual abuse-related PTSD. Psychiatry Research. 2010;183:181-186. [pmid: 20688488].
Lang AJ, Strauss JL, Bomyea J, Bormann JE, Hickman SD, Good RC, et al. The theoretical and empirical basis for meditation as an intervention for PTSD. Behavior Modification. 2012;36(6):759-786. [pmid: 22669968].
Lang JM, Ford JD, Fitzgerald MM. An algorithm for determining use of trauma-focused cognitive–behavioral therapy. Psychotherapy (Chicago). 2010;47:554-569.
Lasiuk GC, Hegadoren KM. Posttraumatic stress disorder part I: Historical development of the concept. Perspectives in Psychiatric Care. 2006;42:13-20. [pmid: 16480413].
Lasiuk GC, Hegadoren KM. Posttraumatic stress disorder part II: Development of the construct within the North American psychiatric taxonomy. Perspectives in Psychiatric Care. 2006;42:72-81. [pmid: 16677131].
Lau EX, Rapee RM. Prevention of anxiety disorders. Current Psychiatry Reports. 2011;13:258-266. [pmid: 21484451].
Laugharne J, Lillee A, Janca A. Role of psychological trauma in the cause and treatment of anxiety and depressive disorders. Current Opinion in Psychiatry. 2010;23:25-29. [pmid: 19901834].
Lavretsky H, Siddarth P, Irwin MR. Improving depression and enhancing resilience in family dementia caregivers: A pilot randomized placebo-controlled trial of escitalopram. The American Journal of Geriatric Psychiatry. 2010;18:154-162. [pmid: 20104071].
Lawyer SR, Resnick HS, Galea S, Ahern J, Kilpatrick DG, Vlahov D. Predictors of peritraumatic reactions and PTSD following the September 11th terrorist attacks. Psychiatry. 2006;69:130-141. [pmid: 16822192].
Layne CM, Warren JS, Saltzman WR, Fulton JB, Steinberg AM, Pynoos RS. Contextual influences on posttraumatic adjustment: Retraumatization and the roles of revictimization, posttraumatic adversities, and distressing reminders. Schein LA, Spitz HI, Burlingame GM, Muskin PR, editors. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:235-286. New York. Haworth Press.
Layne CM, Warren JS, Watson PJ, Shalev AY. Risk, vulnerability, resistance, and resilience: Toward an integrative conceptualization of posttraumatic adaptation. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:497-520. New York, NY. Guilford Press.
Lee BA, Schreck CJ. Danger on the streets: Marginality and victimization among homeless people. American Behavioral Scientist. 2005;48:1055-1081.
Lee CS, Chang JC, Liu CY, Chang CJ, Chen THH, Chen CH, et al. Acculturation, psychiatric comorbidity and posttraumatic stress disorder in a Taiwanese aboriginal population. Social Psychiatry and Psychiatric Epidemiology. 2009;44:55-62. [pmid: 18622537].
Lee E, Mock MR. Asian families: An overview. McGoldrick M, Giordano J, Garcia-Preto N, editors. Ethnicity and family therapy. 3rd ed. 2005:269-289. New York. Guilford Press.
Lee E, Mock MR. Chinese families. McGoldrick M, Giordano J, Garcia-Preto N, editors. Ethnicity and family therapy. 3rd ed. 2005:302-318. New York. Guilford Press.
Lee TT, Westrup DA, Ruzek JI, Keller J, Weitlauf JC. Impact of clinician gender on examination anxiety among female veterans with sexual trauma: A pilot study. Journal of Women’s Health. 2007;16:1291-1299.
Lehmann P, Elliston EJ. Traumatic responding in children exposed to domestic violence: A cross-cultural study. Journal of Ethnic & Cultural Diversity in Social Work: Innovation in Theory, Research & Practice. 2001;10:81-102.
Lensvelt-Mulders G, van der Hart O, van Ochten JM, van Son MJM, Steele K, Breeman L. Relations among peritraumatic dissociation and posttraumatic stress: A meta-analysis. Clinical Psychology Review. 2008;28:1138-1151. [pmid: 18502549].
Lent J. 2010. Stressors and stress management of counselors: Findings from interviews of professional counselors. Retrieved July 4, 2013, from: http://counselingoutfitters.com/vistas/vistas10/Article_73.pdf.
Leserman J, Whetten K, Lowe K, Stangl D, Swartz MS, Thielman NM. How trauma, recent stressful events, and PTSD affect functional health status and health utilization in HIV-infected patients in the south. Psychosomatic Medicine. 2005;67:500-507. [pmid: 15911916].
Lesser L. Review of trauma: A genealogy. Journal of the American Academy of Psychoanalysis. 2003;31:735-738.
Lester KM, Milby JB, Schumacher JE, Vuchinich R, Person S, Clay OJ. Impact of behavioral contingency management intervention on coping behaviors and PTSD symptom reduction in cocaine-addicted homeless. Journal of Traumatic Stress. 2007;20:565-575. [pmid: 17721968].
Lester K, Resick PA, Young-Xu Y, Artz C. Impact of race on early treatment termination and outcomes in posttraumatic stress disorder treatment. Journal of Consulting and Clinical Psychology. 2010;78:480-489. [pmid: 20658805].
Leverich GS, Post RM. Course of bipolar illness after history of childhood trauma. Lancet. 2006;367:1040-1042. [pmid: 16581389].
Levitt JT, Malta LS, Martin A, Davis L, Cloitre M. The flexible application of a manualized treatment for PTSD symptoms and functional impairment related to the 9/11 World Trade Center attack. Behaviour Research and Therapy. 2007;45:1419-1433. [pmid: 17350590].
Lewis KL, Grenyer BF. Borderline personality or complex posttraumatic stress disorder? An update on the controversy. Harvard Review of Psychiatry. 2009;17:322-328. [pmid: 19832046].
Lewis-Fernandez R, Martinez-Taboas A, Sar V, Patel S, Boatin A. The cross-cultural assessment of dissociation. Wilson JP, Tang CS, editors. Cross-cultural assessment of psychological trauma and PTSD. 2007:279-317. New York. Springer Publishing Science + Business Media.
Libby AM, Orton HD, Beals J, Buchwald D, Manson SM. Childhood abuse and later parenting outcomes in two American Indian tribes. Child Abuse & Neglect. 2008;32:195-211. [pmid: 18304630].
Lilly MM, Graham-Bermann SA. Ethnicity and risk for symptoms of posttraumatic stress following intimate partner violence. Journal of Interpersonal Violence. 2009;24:3-19. [pmid: 18299418].
Linehan MM. Dialectical behavior therapy for treatment of borderline personality disorder: Implications for the treatment of substance abuse. Onken LS, Blaine JD, Boren JJ, editors. Behavioral Treatments for Drug Abuse and Dependence. 1993:201-216. Rockville, MD. National Institute on Drug Abuse.
Linley PA, Joseph S, Loumidis K. Trauma work, sense of coherence, and positive and negative changes in therapists. Psychotherapy and Psychosomatics. 2005;74:185-188. [pmid: 15832070].
Litz BT, Gray MJ. Early Intervention for mass violence: What is the evidence? What should be done?. Cognitive and Behavioral Practice. 2002;9:266-272.
Litz BT. Early intervention for trauma: Where are we and where do we need to go? A commentary. Journal of Traumatic Stress. 2008;21:503-506. [pmid: 19107726].
Litz BT, Miller M, Ruef A, McTeague L. 2002. Exposure to trauma in adults. Antony M, Barlow D, editors. Handbook of assessment and treatment planning for psychological disorders. New York. Guilford Press.
Liu D, Diorio J, Day JC, Francis DD, Meaney MJ. Maternal care, hippocampal synaptogenesis and cognitive development in rats. Nature Neuroscience. 2000;3:799-806.
Lockwood A, Steinke DT, Botts SR. Medication adherence and its effect on relapse among patients discharged from a Veterans Affairs posttraumatic stress disorder treatment program. Ann Pharmacother. 2009;43:1227-1232. [pmid: 19584387].
Lommen MJ, Restifo K. Trauma and posttraumatic stress disorder (PTSD) in patients with schizophrenia or schizoaffective disorder. Community Mental Health Journal. 2009;45:485-496. [pmid: 19777347].
Long ME, Grubaugh AL, Elhai JD, Cusack KJ, Knapp R, Frueh BC. Therapist fidelity with an exposure-based treatment of PTSD in adults with schizophrenia of schizoaffective disorder. Journal of Clinical Psychology. 2010;66:383-393. [pmid: 20112407].
Lovell K. What else do we need to know about evidence-based psychological interventions for PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:208-210. Chichester, UK. John Wiley and Sons, Inc.
Lu W, Mueser KT, Rosenberg SD, Jankowski MK. Correlates of adverse childhood experiences among adults with severe mood disorders. Psychiatric Services. 2008;59:1018-1026. [pmid: 18757595].
Luce H, Schrager S, Gilchrist V. Sexual assault of women. American Family Physician. 2010;81:489-495. [pmid: 20148503].
Lueger–Schuster B. Supporting interventions after exposure to torture. Torture. 2010;20:32-44. [pmid: 20228452].
Lunasco TK, Goodwin EA, Ozanian AJ, Loflin EM. One Shot–One Kill: A culturally sensitive program for the warrior culture. Mil Med. 2010;175:509-513. [pmid: 20684455].
Lutz GM, Kramer RE, Gonnerman ME, Lantz GL, Downs WR. 1995. Substance abuse and the Iowa flood disaster of 1993: Final report. Cedar Falls, IA. University of Northern Iowa.
Lynch M, Cicchetti D. An ecological–transactional analysis of children and contexts: The longitudinal interplay among child maltreatment, community violence, and children’s symptomatology. Development and Psychopathology. 1998;10:235-257. [pmid: 9635223].
Lynch SM. Restoring relationships: Group interventions for survivors of sexual traumas. Surviving sexual violence: A guide to recovery and empowerment. 2011:179-198. Lanham, MD. Rowman & Littlefield.
MacDermott D. Psychological hardiness and meaning making as protection against sequelae in veterans of the wars in Iraq and Afghanistan. International Journal of Emergency Mental Health. 2010;12:199-206. [pmid: 21473370].
Macklin ML, Metzger LJ, Litz BT, McNally RJ, Lasko NB, Orr SP, et al. Lower precombat intelligence is a risk factor for posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 1998;66:323-326. [pmid: 9583335].
Mackowiak PA, Batten SV. Post-traumatic stress reactions before the advent of post-traumatic stress disorder: Potential effects on the lives and legacies of Alexander the Great, Captain James Cook, Emily Dickinson, and Florence Nightingale. Military Medicine. 2008;173:1158-1163. [pmid: 19149331].
MacMillan HL, Wathen CN, Jamieson E, Boyle MH, Shannon HS, Ford-Gilboe M, et al. Screening for intimate partner violence in health care settings: A randomized trial. JAMA. 2009;302:493-501. [pmid: 19654384].
Macy RD, Behar L, Paulson R, Delman J, Schmid L, Smith SF. Community-based, acute posttraumatic stress management: A description and evaluation of a psychosocial–intervention continuum. Harvard Review of Psychiatry. 2004;12:217-228. [pmid: 15371064].
Macy RJ, Giattina M, Sangster TH, Crosby C, Montijo NJ. Domestic violence and sexual assault services: Inside the black box. Aggression and Violent Behavior. 2009;14:359-373.
Madrid PA, Grant R, Reilly MJ, Redlener NB. Challenges in meeting immediate emotional needs: Short-term impact of a major disaster on children’s mental health: Building resiliency in the aftermath of Hurricane Katrina. Pediatrics. 2006;117:S448-S453. [pmid: 16735282].
Madsen LH, Blitz LV, McCorkle D, Panzer PG. Sanctuary in a domestic violence shelter: A team approach to healing. Psychiatric Quarterly. 2003;74:155-171. [pmid: 12602831].
Maercker A, Zöllner T, Menning H, Rabe S, Karl A. Dresden PTSD treatment study: Randomized controlled trial of motor vehicle accident survivors. BMC Psychiatry. 2006;6:29. [pmid: 16824221].
Maes M, delmeire L, Mylle J, Atamura C. Risk and preventive factors of post-traumatic stress disorder (PTSD): Alcohol consumption and intoxication prior to a traumatic event diminishes the relative risk to develop PTSD in response to that trauma. Journal of Affective Disorders. 2001;63:113-121. [pmid: 11246087].
Maguen S, Lucenko BA, Reger MA, Gahm GA, Litz BT, Seal KH, et al. The impact of reported direct and indirect killing on mental health symptoms in Iraq War veterans. Journal of Traumatic Stress. 2010;23:86-90. [pmid: 20104592].
Maguen S, Luxton DD, Skopp NA, Madden E. Gender differences in traumatic experiences and mental health in active duty soldiers redeployed from Iraq and Afghanistan. Journal of Psychiatric Research. 2011;46(3):311-316. [pmid: 22172997].
Maguen S, Luxton DD, Skopp NA, Gahm GA, Reger MA, Metzler TJ, et al. Killing in combat, mental health symptoms, and suicidal ideation in Iraq war veterans. Journal of Anxiety Disorders. 2011;25(4):563-567. [pmid: 21333486].
Maguen S, Ren L, Bosch JO, Marmar CR, Seal KH. Gender differences in mental health diagnoses among Iraq and Afghanistan veterans enrolled in veterans affairs health care. American Journal of Public Health. 2010;100:2450-2456. [pmid: 20966380].
Maguen S, Suvak M, Litz BT. Predictors and prevalence of posttraumatic stress disorder among military veterans. Adler AB, Castro CA, Britt TW, editors. Military life: The psychology of serving in peace and combat (Vol 2): Operational stress. 2006:141-169. Westport, CT. Praeger Security International.
Maguire C, McCusker CG, Meenagh C, Mulholland C, Shannon C. Effects of trauma on bipolar disorder: The mediational role of interpersonal difficulties and alcohol dependence. Bipolar Disorder. 2008;10:293-302.
Mahalik JR. Cognitive therapy for men. Brooks GR, Good GE, editors. The new handbook of psychotherapy and counseling with men: A comprehensive guide to settings, problems, and treatment approaches. 2001:544-564. San Francisco, CA. Jossey-Bass.
Maker AH, Kemmelmeier M, Peterson C. Child sexual abuse, peer sexual abuse, and sexual assault in adulthood: A multi-risk model of revictimization. Journal of Traumatic Stress. 2001;14:351-368. [pmid: 11469162].
Makin-Byrd K, Gifford E, McCutcheon S, Glynn S. Family and couples treatment for newly returning veterans. Professional Psychology: Research and Practice. 2011;42:47-55.
Malik ML, Connor KM, Sutherland SM, Smith RD, Davison RM, Davidson JR. Quality of life and posttraumatic stress disorder: A pilot study assessing changes in SF–36 scores before and after treatment in a placebo-controlled trial of fluoxetine. Journal of Traumatic Stress. 1999;12:387-393. [pmid: 10378176].
Malta LS, Levitt JT, Martin A, Davis L, Cloitre M. Correlates of functional impairment in treatment–seeking survivors of mass terrorism. Behavior Therapy. 2009;40:39-49. [pmid: 19187815].
Mancino MJ, Pyne JM, Tripathi S, Constans J, Roca V, Freeman T. Quality-adjusted health status in veterans with posttraumatic stress disorder. Journal of Nervous and Mental Disease. 2006;194:877-879. [pmid: 17102715].
Maniglio R. Severe mental illness and criminal victimization: A systematic review. Acta Psychiatrica Scandinavica. 2009;119:180-191. [pmid: 19016668].
Manson SM, Beals J, Klein SA, Croy CD. Social epidemiology of trauma among 2 American Indian reservation populations. American Journal of Public Health. 2005;95:851-859. [pmid: 15855465].
Marchand A, Guay S, Boyer R, Lucci S, Martin A, St-Hilaire MH. A randomized controlled trial of an adapted form of individual critical incident stress debriefing for victims of an armed robbery. Brief Treatment and Crisis Intervention. 2006;6:122-129.
Marcus S, Dubi M. The relationship between resilience and compassion fatigue in counselors. Walz GR, Bleuer JC, Yep RK, editors. Vistas: Compelling perspectives on counseling 2006. 2006:223-225. Alexandria, VA. American Counseling Association.
Markowitz JC. IPT and PTSD. Depression and Anxiety. 2010;27:879-881. [pmid: 20886608].
Marques L, Robinaugh DJ, LeBlanc NJ, Hinton D. Cross-cultural variations in the prevalence and presentation of anxiety disorders. Expert Review of Neurotherapeutics. 2011;11:313-322. [pmid: 21306217].
Marsella AJ, Christopher MA. Ethnocultural considerations in disasters: An overview of research, issues, and directions. Psychiatric Clinics of North America. 2004;27:521-539. [pmid: 15325491].
Marsella AJ. Ethnocultural aspects of PTSD: An overview of concepts, issues, and treatments. Traumatology. 2010;16:17-26.
Marsella AJ, Johnson JL, Watson P, Gryczynski J. Essential concepts and foundations. Marsella AJ, Johnson JL, Watson P, Gryczynski J, editors. Ethnocultural perspectives on disaster and trauma: Foundations, issues, and applications. 2008:3-13. New York. Springer Publishing Science + Business Media.
Marshall GN, Schell TL, Miles JNV. Ethnic differences in posttraumatic distress: Hispanics symptoms differ in kind and degree. Journal of Consulting and Clinical Psychology. 2009;77:1169-1178. [pmid: 19968392].
Marshall GN, Schell TL, Elliott MN, Berthold SM, Chun CA. Mental health of Cambodian refugees 2 decades after resettlement in the United States. JAMA. 2005;294:571-579. [pmid: 16077051].
Marshall-Berenz EC, Vujanovic AA, Zvolensky MJ. Main and interactive effects of a nonclinical panic attack history and distress tolerance in relation to PTSD symptom severity. Journal of Anxiety Disorders. 2011;25:185-191. [pmid: 20888732].
Martin M, Marchand A, Boyer R, Martin N. Predictors of the development of posttraumatic stress disorder among police officers. Journal of Trauma & Dissociation. 2009;10:451-468. [pmid: 19821179].
Martin SL, Ray N, Sotres-Alvarez D, Kupper LL, Moracco KE, Dickens PA, et al. Physical and sexual assault of women with disabilities. Violence Against Women. 2006;12:823-837. [pmid: 16905675].
Martino S, Canning-Ball M, Carroll KM, Rounsaville BJ. A criterion-based stepwise approach for training counselors in motivational interviewing. Journal of Substance Abuse Treatment. 2011;40:357-365. [pmid: 21316183].
Martorell A, Tsakanikos E. Traumatic experiences and life events in people with intellectual disability. Current Opinion in Psychiatry. 2008;21:445-448. [pmid: 18650684].
Martorell A, Tsakanikos E, Pereda A, Gutierrez-Recacha P, Bouras N, Ayuso-Mateos JL. Mental health in adults with mild and moderate intellectual disabilities: The role of recent life events and traumatic experiences across the life span. Journal of Nervous and Mental Disease. 2009;197:182-186. [pmid: 19282685].
Martsolf DS, Draucker CB, Cook CB, Ross R, Stidham AW, Mweemba P. A meta-summary of qualitative findings about professional services for survivors of sexual violence. Qual.Rep. 2010;15:489-506. [pmid: 21837284].
Maschi T, Brown D. Professional self-care and prevention of secondary trauma. Helping bereaved children: A handbook for practitioners. 3rd ed. 2010:345-373. New York. Guilford Press.
Maschi T, Dennis KS, Gibson S, MacMillan T, Sternberg S, Hom M. Trauma and stress among older adults in the criminal justice system: A review of the literature with implications for social work. Journal of Gerontological Social Work. 2011;54:390-424. [pmid: 21547829].
Masho SW, Ahmed G. Age at sexual assault and posttraumatic stress disorder among women: Prevalence, correlates, and implications for prevention. Journal of Women’s Health. 2007;16:262-271.
Mathieu A, Mazza S, Petit D, Decary A, Massicotte-Marquez J, Malo J, et al. Does age worsen EEG slowing and attention deficits in obstructive sleep apnea syndrome?. Clinical Neurophysiology. 2007;118:1538-1544. [pmid: 17507290].
Maxfield L. Looking back, moving forward. Journal of EMDR Practice and Research. 2009;3:210.
McCabe OL, Lating JM, Everly GS Jr, Mosley AM, Teague PJ, Links JM, et al. Psychological first aid training for the faith community: A model curriculum. International Journal of Emergency Mental Health. 2007;9:181-192. [pmid: 18372660].
McCabe OL, Mosley AM, Gwon HS, Everly GS Jr, Lating JM, Links JM, et al. The tower of ivory meets the house of worship: Psychological first aid training for the faith community. International Journal of Emergency Mental Health. 2007;9:171-180. [pmid: 18372659].
McCaig LF, Burt CW. 2005. National Hospital Ambulatory Medical Care Survey: 2003 emergency department summary. (Rep. No. 358). Hyattsville, MD. National Center for Health Statistics.
McCarthy E, Petrakis I. Epidemiology and management of alcohol dependence in individuals with post-traumatic stress disorder. CNS Drugs. 2010;24:997-1007. [pmid: 21090836].
McCutcheon VV, Heath AC, Nelson EC, Bucholz KK, Madden PA, Martin NG. Clustering of trauma and associations with single and co-occurring depression and panic attack over twenty years. Twin Research and Human Genetics. 2010;13:57-65. [pmid: 20158307].
McDonagh A, Friedman M, McHugo G, Ford J, Sengupta A, Mueser K, et al. Randomized trial of cognitive–behavioral therapy for chronic posttraumatic stress disorder in adult female survivors of childhood sexual abuse. Journal of Consulting and Clinical Psychology. 2005;73:515-524. [pmid: 15982149].
McFall M, Atkins DC, Yoshimoto D, Thompson CE, Kanter E, Malte CA, et al. Integrating tobacco cessation treatment into mental health care for patients with posttraumatic stress disorder. Am.J Addict. 2006;15:336-344. [pmid: 16966189].
McFarlane AC. Phenomenology of posttraumatic stress disorder. Stein DJ, Hollander E, Rothbaum BO, editors. Textbook of anxiety disorders. 2nd ed. 2010:547-565. Arlington, VA. American Psychiatric Publishing, Inc.
McFarlane AC. Redefining PTSD in DSM-V: Conundrums and potentially unintended risks. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:42-47. Chichester, UK. John Wiley and Sons, Inc.
McGarrigle T, Walsh CA. Mindfulness, self-care, and wellness in social work: Effects of contemplative training. Journal of Religion & Spirituality in Social Work: Social Thought. 2011;30:212-233.
McGovern MP, Lambert-Harris C, Acquilano S, Xie H, Alterman AI, Weiss RD. A cognitive behavioral therapy for co-occurring substance use and posttraumatic stress disorders. Addictive Behaviors. 2009;34:892-897. [pmid: 19395179].
McGovern MP, Lambert-Harris C, Alterman AI, Xie H, Meier A. A randomized controlled trial comparing integrated cognitive behavioral therapy versus individual addiction counseling for co-occurring substance use and posttraumatic stress disorders. Journal of Dual Diagnosis. 2011;7:207-227. [pmid: 22383864].
McHugh PR, Treisman G. PTSD: A problematic diagnostic category. Journal of Anxiety Disorders. 2007;21:211-222. [pmid: 17085011].
McHugo GJ, Caspi Y, Kammerer N, Mazelis R, Jackson EW, Russell L, et al. The assessment of trauma history in women with co-occurring substance abuse and mental disorders and a history of interpersonal violence. The Journal of Behavioral Health Services & Research. 2005;32:113-127. [pmid: 15834262].
McLaughlin KA, Green JG, Gruber MJ, Sampson NA, Zaslavsky AM, Kessler RC. Childhood adversities and adult psychopathology in the National Comorbidity Survey Replication (NCS–R) III: Associations with functional impairment related to DSM-IV disorders. Psychological Medicine. 2010;40:847-859. [pmid: 19732483].
McLaughlin KA, Green JG, Gruber MJ, Sampson NA, Zaslavsky AM, Kessler RC. Childhood adversities and adult psychiatric disorders in the National Comorbidity Survey Replication II: Associations with persistence of DSM-IV disorders. Archives of General Psychiatry. 2010;67:124-132. [pmid: 20124112].
McLay RN, Klam WP, Volkert SL. Insomnia is the most commonly reported symptom and predicts other symptoms of post-traumatic stress disorder in U.S. service members returning from military deployments. Military Medicine. 2010;175:759-762. [pmid: 20968266].
McLean CP, Anderson ER. Brave men and timid women? A review of the gender differences in fear and anxiety. Clinical Psychology Review. 2009;29:496-505. [pmid: 19541399].
McLean CP, Foa EB. Prolonged exposure therapy for post-traumatic stress disorder: A review of evidence and dissemination. Expert Review of Neurotherapeutics. 2011;11:1151-1163. [pmid: 21797656].
McLean CP, Asnaani A, Litz BT, Hofmann SG. Gender differences in anxiety disorders: Prevalence, course of illness, comorbidity and burden of illness. Journal of Psychiatric Research. 2011;45:1027-1035. [pmid: 21439576].
McLean CP, Steenkamp MM, Levy HC, Litz BT. Posttraumatic stress disorder. Cucciare MA, Weingardt KR, editors. Using technology to support evidence-based behavioral health practices: A clinician’s guide. 2010:45-68. New York. Routledge/Taylor & Francis Group.
McLeod DS, Koenen KC, Meyer JM, Lyons MJ, Eisen S, True W, et al. Genetic and environmental influences on the relationship among combat exposure, posttraumatic stress disorder symptoms, and alcohol use. Journal of Traumatic Stress. 2001;14:259-275. [pmid: 11469155].
McLeod J. 1997. Narrative and psychotherapy. London. Sage Publications.
McNally RJ. 2003. Remembering trauma. Cambridge, MA. Belknap Press. of. Harvard University Press.
McNally RJ. Debunking myths about trauma and memory. The Canadian Journal of Psychiatry/La Revue Canadienne de Psychiatrie. 2005;50:817-822.
McNally RJ, Bryant RA, Ehlers A. Does early psychological intervention promote recovery from posttraumatic stress?. Psychological Science in the Public Interest. 2003;4:45-79.
McNamara C, Schumacher JE, Milby JB, Wallace D, Usdan S. Prevalence of nonpsychotic mental disorders does not affect treatment outcome in a homeless cocaine-dependent sample. American Journal of Drug and Alcohol Abuse. 2001;27:91-106. [pmid: 11373038].
McWilliams LA, Cox BJ, Enns MW. Mood and anxiety disorders associated with chronic pain: An examination in a nationally representative sample. Pain. 2003;106:127-133. [pmid: 14581119].
Mead S, MacNeil C. Peer support: What makes it unique?. International Journal of Psychosocial Rehabilitation. 2006;10:29-38.
Mead S. 2008. Intentional peer support: An alternative approach. Plainfield, NH. Shery Mead Consulting.
Meaney MJ, Brake W, Gratton A. Environmental regulation of the development of mesolimbic dopamine systems: A neurobiological mechanism for vulnerability to drug abuse?. Psychoneuroendocrinology. 2002;27:127-138. [pmid: 11750774].
Meichenbaum D. 1994. A clinical handbook/practical therapist manual for assessing and treating adults with post-traumatic stress disorder (PTSD). Waterloo, Ontario. Institute Press.
Meichenbaum D. Stress inoculation training for coping with stressors. The Clinical Psychologist. 1996;49:4-7.
Meichenbaum D. Stress inoculation training: A preventative and treatment approach. Principles and practice of stress management. 3rd ed. 2007:497-516. New York. Guilford Press.
Meichenbaum DH, Deffenbacher JL. Stress inoculation training. Counseling Psychologist. 1988;16:69-90.
Meis LA, Barry RA, Kehle SM, Erbes CR, Polusny MA. Relationship adjustment, PTSD symptoms, and treatment utilization among coupled National Guard soldiers deployed to Iraq. Journal of Family Psychology. 2010;24:560-567. [pmid: 20954766].
Mello MF. Critical view of the pharmacological treatment of trauma. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:163. Chichester, UK. John Wiley and Sons, Inc.
Melnick SM, Bassuk EL. 2000. Identifying and responding to violence among poor and homeless women. Nashville, TN. National Health Care for the Homeless Council.
Meltzer-Brody S, Churchill E, Davidson JRT. Derivation of the SPAN, a brief diagnostic screening test for post-traumatic stress disorder. Psychiatry Research. 1999;88:63-70. [pmid: 10641587].
Mendenhall TJ, Berge JM. Family therapists in trauma-response teams: Bringing systems thinking into interdisciplinary fieldwork. Journal of Family Therapy. 2010;32:43-57.
Mendenhall TJ. Trauma-response teams: Inherent challenges and practical strategies in interdisciplinary fieldwork. Families, Systems, & Health. 2006;24:357-362.
Mendes DD, Mello MF, Ventura P, Passarela CM, Mari JJ. A systematic review on the effectiveness of cognitive behavioral therapy for posttraumatic stress disorder. International Journal of Psychiatry in Medicine. 2008;38:241-259. [pmid: 19069570].
Mental Health America Centers for Technical Assistance. 2012. Trauma Recovery and Empowerment Model (TREM). Alexandria, VA. Mental Health America, Centers for Technical Assistance.
Merikangas KR, Akiskal HS, Angst J, Greenberg PE, Hirschfeld RM, Petukhova M, et al. Lifetime and 12-month prevalence of bipolar spectrum disorder in the National Comorbidity Survey replication. Archives of General Psychiatry. 2007;64:543-552. [pmid: 17485606].
Mevissen L, de Jongh A. PTSD and its treatment in people with intellectual disabilities: A review of the literature. Clinical Psychology Review. 2010;30:308-316. [pmid: 20056303].
Meyer RE. Psychobiology and the treatment of drug dependence: The biobehavioral interface. American Journal of Drug and Alcohol Abuse. 1986;12:223-233. [pmid: 3332558].
Meyerbröker K, Emmelkamp PM. Virtual reality exposure therapy in anxiety disorders: A systematic review of process-and-outcome studies. Depression and Anxiety. 2010;27:933-944. [pmid: 20734361].
Miller D, Guidry L. 2001. Addictions and trauma recovery: Healing the body, mind, and spirit. New York. W.W. Norton.
Miller GH. The trauma of insidious racism. Journal of the Academy of Psychiatry and the Law. 2009;37:41-44.
Miller KE, Weine SM, Ramic A, Brkic N, Bjedic ZD, Smajkic A, et al. The relative contribution of war experiences and exile-related stressors to levels of psychological distress among Bosnian refugees. Journal of Traumatic Stress. 2002;15:377-387. [pmid: 12392225].
Miller NA, Najavits LM. Creating trauma-informed correctional care: A balance of goals and environment. European Journal of Psychotraumatology. 2012;3. 2012. including Supplements.
Miller WR, Rollnick S. 2002. Motivational interviewing: Preparing people for change. 2nd ed. New York. Guilford Press.
Mills KL, Teesson M, Ross J, Peters L. Trauma, PTSD, and substance use disorders: findings from the Australian National Survey of Mental Health and Well–Being. American Journal of Psychiatry. 2006;163:652-658. [pmid: 16585440].
Mitchell JT, Everly GS. Critical incident stress management and critical incident stress debriefings: Evolutions, effects and outcomes. Raphael B, Wilson J, editors. Psychological debriefing: Theory, practice and evidence. 2000:71-90. Cambridge. Cambridge University Press.
Mitchell JT, Everly GS Jr. 2001. Critical Incident Stress Debriefing: An operations manual for CISD, defusing and other group crisis intervention services. 3. Ellicott City, MD. Chevron Publishing Corporation.
Moak ZB, Agrawal A. The association between perceived interpersonal social support and physical and mental health: Results from the National Epidemiological Survey on Alcohol and Related Conditions. Journal of Public Health: Oxford Journals. 2010;32:191-201.
Mock SE, Arai SM. Childhood trauma and chronic illness in adulthood: Mental health and socioeconomic status as explanatory factors and buffers. Frontiers in Psychology. 2010;1:246. [pmid: 21833299].
Moffitt TE, Caspi a, Taylor A, Kokaua J, Milne BJ, Polanczyk G, et al. How common are common mental disorders? Evidence that lifetime prevalence rates are doubled by prospective versus retrospective ascertainment. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2010;40:899-909.
Mollica RF. 2009. Healing invisible wounds: Paths to hope and recovery in a violent world. Nashville, TN. Vanderbilt University Press.
Mollica RF, McInnes K, Poole C, Tor S. Dose–effect relationships of trauma to symptoms of depression and post-traumatic stress disorder among Cambodian survivors of mass violence. British Journal of Psychiatry. 1998;173:482-488. [pmid: 9926076].
Mollick L, Spett M. 2002. Cloitre: Why exposure fails with most PTSD patients. Cranford, NJ. NJ Association of Cognitive–Behavioral Therapistsl.
Monson CM, Fredman SJ, Dekel R. Posttraumatic stress disorder in an interpersonal context. Beck GJ, editor. Interpersonal processes in the anxiety disorders: Implications for understanding psychopathology and treatment. 2010:179-208. Washington, DC. American Psychological Association.
Monson CM, Rodriguez BF, Warner R. Cognitive–behavioral therapy for PTSD in the real world: Do interpersonal relationships make a real difference?. Journal of Clinical Psychology. 2005;61:751-761. [pmid: 15546144].
Monson CM, Schnurr PP, Resick PA, Friedman MJ, Young-Xu Y, Stevens SP. Cognitive processing therapy for veterans with military-related posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2006;74:898-907. [pmid: 17032094].
Monson CM, Stevens SP, Schnurr PP. Cognitive–behavioral couple’s treatment for posttraumatic stress disorder. Corales TA, editor. Focus on posttraumatic stress disorder research. 2005:245-274. Hauppauge, NY. Nova Science Publishers.
Monson CM, Taft CT, Fredman SJ. Military-related PTSD and intimate relationships: From description to theory-driven research and intervention development. Clinical Psychology Review. 2009;29:707-714. [pmid: 19781836].
Montoya ID, Covarrubias LD, Patek JA, Graves JA. Posttraumatic stress disorder among Hispanic and African-American drug users. The American Journal of Drug and Alcohol Abuse. 2003;29:729-741. [pmid: 14713136].
Moore BA, Kennedy CH. 2011. Wheels down: Adjusting to life after deployment. 1st ed. Washington, DC. American Psychological Association.
Morland LA, Greene CJ, Grubbs K, Kloezeman K, Mackintosh MA, Rosen C, et al. Therapist adherence to manualized cognitive–behavioral therapy for anger management delivered to veterans with PTSD via videoconferencing. Journal of Clinical Psychology. 2011;67:629-638. [pmid: 21360528].
Morrissey JP, Ellis AR, Gatz M, Amaro H, Reed BG, Savage A, et al. Outcomes for women with co-occurring disorders and trauma: Program and person-level effects. Journal of Substance Abuse Treatment. 2005;28:121-133. [pmid: 15780541].
Morrissey JP, Jackson EW, Ellis AR, Amaro H, Brown VB, Najavits LM. Twelve-month outcomes of trauma-informed interventions for women with co-occurring disorders. Psychiatric Services. 2005;56:1213-1222. [pmid: 16215186].
Morsette A, Swaney G, Stolle D, Schuldberg D, van den Pol R, Young M. Cognitive behavioral intervention for trauma in schools (CBITS): School-based treatment on a rural American Indian reservation. Journal of Behavior Therapy and Experimental Psychiatry. 2009;40:169-178. [pmid: 18835478].
Moses DJ, Reed BG, Mazelis R, D’Ambrosio B. 2003. Creating trauma services for women with co-occurring disorders: Experiences from the SAMHSA Women with Alcohol, Drug Abuse and Mental Health Disorders Who Have Histories of Violence Study. Rockville, MD. Substance Abuse And Mental Health Services Administration.
Mota NP, Medved M, Wang J, Asmundson GJ, Whitney D, Sareen J. Stress and mental disorders in female military personnel: Comparisons between the sexes in a male dominated profession. J. Psychiatr Res. 2012;46:159-167. [pmid: 22024487].
Moul DE, Hall M, Pilkonis PA, Buysse DJ. Self-report measures of insomnia in adults: rationales, choices, and needs. Sleep Medicine Reviews. 2004;8:177-198. [pmid: 15144961].
Mouton CP, Rodabough RJ, Rovi SL, Hunt JL, Talamantes MA, Brzyski RG, et al. Prevalence and 3-year incidence of abuse among postmenopausal women. American Journal of Public Health. 2004;94:605-612. [pmid: 15054013].
Mueser KT, Bolton E, Carty PC, Bradley MJ, Ahlgren KF, Distaso DR, et al. The Trauma Recovery Group: A cognitive–behavioral program for post-traumatic stress disorder in persons with severe mental illness. Community Mental Health Journal. 2007;43:281-304. [pmid: 17235698].
Mueser KT, Essock SM, Haines M, Wolfe R, Xie H. Posttraumatic stress disorder, supported employment, and outcomes in people with severe mental illness. CNS Spectrums. 2004;9:913-925. [pmid: 15616477].
Mueser KT, Rosenberg SD, Xie H, Jankowski MK, Bolton EE, Lu W, et al. A randomized controlled trial of cognitive–behavioral treatment for posttraumatic stress disorder in severe mental illness. Journal of Consulting & Clinical Psychology. 2008;76:259-271. [pmid: 18377122].
Mueser KT, Salyers MP, Rosenberg SD, Goodman LA, Essock SM, Osher FC, et al. Interpersonal trauma and posttraumatic stress disorder in patients with severe mental illness: Demographic, clinical, and health correlates. Schizophrenia Bulletin. 2004;30:45-57. [pmid: 15176761].
Myers DG, Wee DF. Strategies for managing disaster mental health worker stress. Figley CR, editor. Treating compassion fatigue. 2002:181-211. New York. Brunner-Routledge.
Mylle J, Maes M. Partial posttraumatic stress disorder revisited. Journal of Affective Disorders. 2004;78:37-48. [pmid: 14672795].
Nader K. Review of when helping hurts: Preventing and treating compassion fatigue. Traumatology. 2008;14:148.
Najavits L. 2012. PTSD. Newton Centre, MA. Treatment Innovations.
Najavits LM. 2002. Seeking safety: A treatment manual for PTSD and substance abuse. New York. Guilford Press.
Najavits LM. 2002. Seeking Safety: Psychotherapy for PTSD and substance abuse. Belmont, MA. McLean Hospital.
Najavits LM. Assessment of trauma, PTSD, and substance use disorder: A practical guide. Wilson JP, Keane T, editors. Assessing psychological trauma and PTSD. 2004:466-491. New York. Guilford.
Najavits LM. Psychosocial treatments for posttraumatic stress disorder. Nathan PE, Gorman EM, editors. A guide to treatments that Work. 3d ed. 2007:513-530. New York. Oxford Press.
Najavits LM. Seeking safety: An evidence-based model for substance abuse and trauma/PTSD. Therapist’s guide to evidence-based relapse prevention. 2007:141-167. San Diego, CA. Elsevier. Academic Press.
Najavits LM, Gastfriend DR, Barber JP, Reif S, Muenz LR, Blaine J, et al. Cocaine dependence with and without PTSD among subjects in the National Institute on Drug Abuse Collaborative Cocaine Treatment Study. American Journal of Psychiatry. 1998;155:214-219. [pmid: 9464200].
Najavits LM, Griffin ML, Luborsky L, Frank A, Weiss RD, Liese BS, et al. Therapists’ emotional reactions to substance abusers: A new questionnaire and initial findings. Psychotherapy: Theory, Research, Practice, Training. 1995;32:669-677.
Najavits LM, Harned MS, Gallop RJ, Butler SF, Barber JP, Thase ME, et al. Six-month treatment outcomes of cocaine-dependent patients with and without PTSD in a multisite national trial. Journal of Studies on Alcohol and Drugs. 2007;68:353-361. [pmid: 17446974].
Najavits LM, Ryngala D, Back SE, Bolton E, Mueser KT, Brady KT. Treatment of PTSD and comorbid disorders. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:508-535. New York. Guilford Press.
Najavits LM, Schmitz M, Gotthardt S, Weiss RD. Seeking safety plus exposure therapy: An outcome study on dual diagnosis men. Journal of Psychoactive Drugs. 2005;37:425-435. [pmid: 16480170].
Najavits LM, Sonn J, Walsh M, Weiss RD. Domestic violence in women with PTSD and substance abuse. Addictive Behaviors. 2004;29:707-715. [pmid: 15135552].
Najavits LM, Weiss RD, Shaw SR. The link between substance abuse and posttraumatic stress disorder in women: A research review. American Journal on Addictions. 1997;6:273-283. [pmid: 9398925].
Najavits LM, Weiss RD, Reif S, Gastfriend DR, Siqueland L, Barber JP, et al. The Addiction Severity Index as a screen for trauma and posttraumatic stress disorder. Journal of Studies on Alcohol. 1998;59:56-62. [pmid: 9498316].
Nandi A, Galea S, Tracy M, Ahern J, Resnick H, Gershon R, et al. Job loss, unemployment, work stress, job satisfaction, and the persistence of posttraumatic stress disorder one year after the September 11 attacks. Journal of Occupational and Environmental Medicine. 2004;46:1057-1064. [pmid: 15602180].
Nappi CM, Drummond SP, Hall JM. Treating nightmares and insomnia in posttraumatic stress disorder: A review of current evidence. Neuropharmacology. 2012;62:576-585. [pmid: 21396945].
Narrow WE, Rae DS, Robins LN, Regier DA. Revised prevalence based estimates of mental disorders in the United States: using a clinical signficance criterion to reconcile 2 surveys’ estimates. Archives of General Psychiatry. 2002;59:115-123. [pmid: 11825131].
National Association of State Mental Health Program Directors. 2004. The damaging consequences of violence and trauma: Facts, discussion points and recommendations for the behavioral health system. Alexandria, VA. National Association of State Mental Health Program Directors.
National Association of State Mental Health Program Directors. 2005. Trauma informed care (TIC) planning guidelines for use in developing an organizational action plan [Draft]. Alexandria, VA. National Association of State Mental Health Program Directors.
National Center for Post-Traumatic Stress Disorder. 2002. Working with trauma survivors. White River Junction, VT. National Center for Post-Traumatic Stress Disorder.
National Center for PTSD. 2007. Chart – Adult PTSD interviews. White River Junction, VT. National Center for PTSD.
National Center for PTSD. 2007. Chart – Adult PTSD self-report measures. White River Junction, VT. National Center for PTSD.
National Center for PTSD. 2007. Chart – screens for PTSD. White River Junction, VT. National Center for PTSD.
National Center for PTSD US Department of Veterans Affairs. 2010. Understanding PTSD. White River Junction, VT. National Center for PTSD.
National Center for Trauma-Informed Care, Center for Mental Health Services. 2011. Psychological trauma. Beau Bassin, Mauritius. Betascript Publishing.
National Child Traumatic Stress Network & National Center for PTSD. 2012. Psychological first aid. Los Angeles. National Center for Child Traumatic Stress.
National Child Traumatic Stress Network. 2012. Neglect. Los Angeles. National Child Traumatic Stress Network.
National Child Traumatic Stress Network, Child Sexual Abuse Task Force and Research & Practice Core. 2004. How to implement trauma-focused cognitive behavioral therapy (TF–CBT). (Rep. No. Version 2). Durham, NC and Los Angeles. National Center for Child Traumatic Stress.
National Coalition for the Homeless. 2002. Why are people homeless?. Washington DC. National Coalition for the Homeless.
National Coalition for the Homeless. 2004. Who is homeless?. Washington, DC. National Coalition for the Homeless.
National Collaborating Centre for Mental Health. 2005. Post-traumatic stress disorder (PTSD): The management of PTSD in adults and children in primary and secondary care. Leicester, UK. National Collaborating Centre for Mental Health.
National Institute for Health and Clinical Excellence. 2005. Post-traumatic stress disorder (PTSD) (CG26). London. National Institute for Health and Clinical Excellence.
National Institute of Mental Health. 2002. Mental health and mass violence: Evidence-based early psychological intervention for victims/survivors of mass violence A workshop to reach consensus on best practices. Washington, DC. U. S. Government Printing Office.
Nebelkopf E, Wright S. Holistic system of care: A ten-year perspective. Journal of Psychoactive Drugs. 2011;43:302-308. [pmid: 22400461].
Nelson EC, Heath AC, Madden PAF, Cooper ML, Dinwiddie SH, Bucholz KK, et al. Association between self-reported childhood sexual abuse and adverse psychosocial outcomes: results from a twin study. Archives of General Psychiatry. 2002;59:139-145. [pmid: 11825135].
Nelson SD. The posttraumatic growth path: An emerging model for prevention and treatment of trauma-related behavioral health conditions. Journal of Psychotherapy Integration. 2011;21:1-42.
Nelson-Zlupko L, Dore MM, Kauffman E, Kaltenbach K. Women in recovery: Their perceptions of treatment effectiveness. Journal of Substance Abuse Treatment. 1996;13:51-59. [pmid: 8699543].
Nemeroff CB, Bremner JD, Foa EB, Mayberg HS, North CS, Stein MB. Posttraumatic stress disorder: A state-of-the-science review. Journal of Psychiatric Research. 2006;40:1-21. [pmid: 16242154].
Neuner F, Schauer M, Klaschik C, Karunakara U, Elbert T. A comparison of narrative exposure therapy, supportive counseling, and psychoeducation for treating posttraumatic stress disorder in an African refugee settlement. Journal of Consulting and Clinical Psychology. 2004;72:579-587. [pmid: 15301642].
New Logic Organizational Learning. 2011. Creating a culture of care: A toolkit for creating a trauma-informed environment. Austin, TX. New Logic Organizational Learning.
New South Wales Institute of Psychiatry & Centre for Mental Health. 2000. Disaster mental health response handbook: An educational resource for mental health professionals involved in disaster management. Parramatta, New South Wales. New South Wales Institute of Psychiatry.
New AS, Fan J, Murrough JW, Liu X, Liebman RE, Guise KG, et al. A functional magnetic resonance imaging study of deliberate emotion regulation in resilience and posttraumatic stress disorder. Biological Psychiatry. 2009;66:656-664. [pmid: 19589502].
Newell JM, MacNeil GA. Professional burnout, vicarious trauma, secondary traumatic stress, and compassion fatigue: A review of theoretical terms, risk factors, and preventive methods for clinicians and researchers. Best Practices in Mental Health: An International Journal. 2010;6:57-68.
Newman JM, Turnbull A, Berman BA, Rodrigues S, Serper MR. Impact of traumatic and violent victimization experiences in individuals with schizophrenia and schizoaffective disorder. Journal of Nervous and Mental Disease. 2010;198:708-714. [pmid: 20921860].
Ng AT, Kantor EM. Psychological first aid. Stoddard FJ, Katz CL, Merlino JP, editors. Hidden impact: What you need to know for the next disaster: A practical mental health guide for clinicians. 2010:115-123. Sudbury, MA. Jones and Bartlett Publishers.
Ng AT. Cultural diversity in the integration of disaster mental health and public health: A case study in response to bioterrorism. International Journal of Emergency Mental Health. 2005;7:23-31. [pmid: 15869078].
Nguyen L. The ethics of trauma: Re-traumatization in society’s approach to the traumatized subject. Int J Group Psychother. 2011;61:26-47. [pmid: 21244199].
Nickerson A, Bryant RA, Silove D, Steel Z. A critical review of psychological treatments of posttraumatic stress disorder in refugees. Clinical Psychology Review. 2011;31:399-417. [pmid: 21112681].
Nishith P, Duntley SP, Domitrovich PP, Uhles ML, Cook BJ, Stein PK. Effect of cognitive behavioral therapy on heart rate variability during REM sleep in female rape victims with PTSD. Journal of Traumatic Stress. 2003;16:247-250. [pmid: 12816336].
Nishith P, Mechanic MB, Resick PA. Prior interpersonal trauma: The contribution to current PTSD symptoms in female rape victims. Journal of Abnormal Psychology. 2000;109:20-5. [pmid: 10740932].
Nishith P, Resick PA, Griffin MG. Pattern of change in prolonged exposure and cognitive–processing therapy for female rape victims with posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2002;70:880-886. [pmid: 12182271].
Nixon RDV, Nearmy DM. Treatment of comorbid posttraumatic stress disorder and major depressive disorder: A pilot study. Journal of Traumatic Stress. 2011;24:451-455. [pmid: 21755543].
Noether CD, Finkelstein N, VanDeMark NR, Savage A, Reed BG, Moses DJ. Design strengths and issues of SAMHSA’s Women, Co-occurring Disorders, and Violence Study. Psychiatric Services. 2005;56:1233-1236. [pmid: 16215188].
Noll JG, Horowitz LA, Bonanno GA, Trickett PK, Putnam FW. Revictimization and self-harm in women who experienced childhood sexual abuse: Results from a prospective study. Journal of Interpersonal Violence. 2003;18:1452-1471. [pmid: 14678616].
Norman SB, Tate SR, Wilkins KC, Cummins K, Brown SA. Posttraumatic stress disorder’s role in integrated substance dependence and depression treatment outcomes. Journal of Substance Abuse Treatment. 2010;38:346-355. [pmid: 20363091].
Norris FH, Slone LB. The epidemiology of trauma and PTSD. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:78-98. New York. Guilford Press.
Norris FH, Friedman MJ, Watson PJ. 60,000 disaster victims speak: Part II. Summary and implications of the disaster mental health research. Psychiatry. 2002;65:240-260. [pmid: 12405080].
Norris FH, Friedman MJ, Watson PJ, Byrne CM, Diaz E, Kaniasty K. 60,000 disaster victims speak: Part I. An empirical review of the empirical literature, 1981–2001. Psychiatry. 2002;65:207-239. [pmid: 12405079].
Norris FH, Kaniasty KZCML, Inman GLMAD. Placing age differences in cultural context: A comparison of the effects of age on PTSD after disasters in the United States, Mexico, and Poland. Journal of Clinical Geropsychology. 2002;8:153-173.
Norris FH, Murphy AD, Baker CK, Perilla JL. Severity, timing, and duration of reactions to trauma in the population: An example from Mexico. Biological Psychiatry. 2003;53:769-778. [pmid: 12725969].
Norris FH, Perilla JL, Ibanez GE, Murphy AD. Sex differences in symptoms of posttraumatic stress: Does culture play a role?. Journal of Traumatic Stress. 2001;14:7-28.
North CS, Eyrich KM, Pollio DE, Spitznagel EL. Are rates of psychiatric disorders in the homeless population changing?. American Journal of Public Health. 2004;94:103-108. [pmid: 14713706].
Norton PJ, Price EC. A meta-analytic review of adult cognitive–behavioral treatment outcome across the anxiety disorders. Journal of Nervous and Mental Disease. 2007;195:521-531. [pmid: 17568301].
Nugent NR, Amstadter AB, Koenen KC. Genetics of post-traumatic stress disorder: informing clinical conceptualizations and promoting future research. Am. J. Med. Genet. C. Semin. Med. Genet. 2008;148C:127-132. [pmid: 18412098].
Obasaju MA, Palin FL, Jacobs C, Anderson P, Kaslow NJ. Won’t you be my neighbor?: Using an ecological approach to examine the impact of community on revictimization. Journal of Interpersonal Violence. 2009;24:38-53. [pmid: 18319364].
O’Donnell C, Cook JM. 2006. Cognitive–behavioral therapies for psychological trauma and comorbid substance use disorders. Carruth B, editor. Psychological trauma and addiction treatment. New York. Haworth Press.
O’Donnell ML, Creamer M, Cooper J. Criterion A: Controversies and clinical implications. Rosen GM, editor. Clinician’s guide to posttraumatic stress disorder. 2010:51-75. Hoboken, NJ. John Wiley and Sons, Inc.
Office of Applied Studies. 2002. Results from the 2001 National Household Survey on Drug Abuse: Vol 1 Summary of national findings. (Rep. No. HHS Publication No. (SMA) 02–3758). Rockville MD. Substance Abuse and Mental Health Services Administration.
Office of the Surgeon Multi-National Corps–Iraq & Office of The Surgeon General United States Army Medical Command. 2006. Mental Health Advisory Team (MHAT) IV Operation Iraqi Freedom 05–07. Final Report 17. November. Washington, DC. U S Army Medical Department.
O’Hare T, Sherrer M. Drinking motives as mediators between PTSD symptom severity and alcohol consumption in persons with severe mental illnesses. Addictive Behaviors. 2011;36:465-469. [pmid: 21315519].
O’Hare T, Sherrer MV. Impact of the most frequently reported traumatic events on community mental health clients. Journal of Human Behavior in the Social Environment. 2009;19:186-195.
O’Hare T, Shen C, Sherrer M. High-risk behaviors and drinking-to-cope as mediators of lifetime abuse and PTSD symptoms in clients with severe mental illness. Journal of Traumatic Stress. 2010;23:255-263. [pmid: 20419734].
O’Hare T, Sherrer MV, Shen C. Subjective distress from stressful events and high-risk behaviors as predictors of PTSD symptom severity in clients with severe mental illness. Journal of Traumatic Stress;Journal of Traumatic Stress. 2006;19:375-386.
Ohayon MM, Shapiro CM. Sleep disturbances and psychiatric disorders associated with posttraumatic stress disorder in the general population. Comprehensive Psychiatry. 2000;41:469-478. [pmid: 11086154].
Ohio Legal Rights Service. 2007. Trauma informed treatment in behavioral health settings. Columbus, OH. Ohio Legal Rights Service.
Okuda M, Olfson M, Hasin D, Grant BF, Lin KH, Blanco C. Mental health of victims of intimate partner violence: Results from a national epidemiologic survey. Psychiatric Services. 2011;62:959-962. [pmid: 21807838].
Olatunji BO, Cisler JM, Tolin DF. Quality of life in the anxiety disorders: A meta-analytic review. Clinical Psychology Review. 2007;27:572-581. [pmid: 17343963].
Olatunji BO, Cisler JM, Tolin DF. 2010. A meta-analysis of the influence of comorbidity on treatment outcome in the anxiety disorders. Clinical Psychology Review.
Olff M, Langeland W, Draijer N, Gersons BPR. Gender differences in posttraumatic stress disorder. Psychological Bulletin. 2007;133:183-204. [pmid: 17338596].
Oman D, Hedberg J, Thoresen CE. Passage meditation reduces perceived stress in health professionals: A randomized, controlled trial. Journal of Consulting and Clinical Psychology. 2006;74:714-719. [pmid: 16881779].
Ompad DC, Ikeda RM, Shah N, Fuller CM, Bailey S, Morse E, et al. Childhood sexual abuse and age at initiation of injection drug Use. American Journal of Public Health. 2005;95:703-709. [pmid: 15798133].
Opler LA, Grennan MS, Ford JD. Pharmacotherapy. Courtois CA, Ford JD, editors. Treating complex traumatic stress disorders: An evidence-based guide. 2009:329-349. New York. Guilford Press.
Orsillo SM. Measures for acute stress disorder and posttraumatic stress disorder. Antony MM, Orsillo SM, Roemer L, editors. Practitioner’s guide to empirically based measures of anxiety. 2001:255-307. Dordrecht, Netherlands. Kluwer Academic Publishers.
Orsillo SM. Measures for social phobia. Antony MM, Orsillo SM, Roemer L, editors. Practitioner’s guide to empirically based measures of anxiety. 2001:165-187. Dordrecht, Netherlands. Kluwer Academic Publishers.
Ortega AN, Rosenheck R. Mental and physical health and acculturation among Hispanic Vietnam veterans. Military Medicine. 2001;166:894-897. [pmid: 11603242].
Ortlepp K, Friedman M. Prevalence and correlates of secondary traumatic stress in workplace lay trauma counselors. Journal of Traumatic Stress. 2002;15:213-222. [pmid: 12092913].
Osterman JE, de Jong JTVM. Cultural issues and trauma. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:425-446. New York. Guilford Press.
Otis JD, Keane TM, Kerns RD, Monson C, Scioli E. The development of an integrated treatment for veterans with comorbid chronic pain and posttraumatic stress disorder. Pain Medicine. 2009;10:1300-1311. [pmid: 19818040].
Otte C. Cognitive behavioral therapy in anxiety disorders: Current state of the evidence. Dialogues in Clinical Neuroscience. 2011;13:413-421. [pmid: 22275847].
Otto MW, Hinton DE. Modifying exposure-based CBT for Cambodian refugees with posttraumatic stress disorder. Cognitive and Behavioral Practice. 2006;13:261-270. [pmid: 20072706].
Ougrin D. Efficacy of exposure versus cognitive therapy in anxiety disorders: Systematic review and meta-analysis. BMC Psychiatry. 2011;11:200. [pmid: 22185596].
Ouimette P, Brown PJ. 2003. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. Washington, DC. American Psychological Association.
Ouimette PC, Ahrens C, Moos RH, Finney JW. During treatment changes in substance abuse patients with posttraumatic stress disorder: The influence of specific interventions and program environments. Journal of Substance Abuse Treatment. 1998;15:555-564. [pmid: 9845869].
Ouimette PC, Brown PJ, Najavits LM. Course and treatment of patients with both substance use and posttraumatic stress disorders. Addictive Behaviors. 1998;23:785-795. [pmid: 9801716].
Ouimette P, Moos RH, Brown PJ. Substance use disorder–posttraumatic stress disorder comorbidity: A survey of treatments and proposed practice guidelines. Ouimette P, Brown PJ, editors. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. 2003:91-110. Washington, DC. American Psychological Association.
Overmier JB, Murison R. Trauma and resulting sensitization effects are modulated by psychological factors. Psychoneuroendocrinology. 2005;30:965-973. [pmid: 15963654].
Owens GP, Steger MF, Whitesell AA, Herrera CJ. Posttraumatic stress disorder, guilt, depression, and meaning in life among military veterans. Journal of Traumatic Stress. 2009;22:654-657. [pmid: 19924820].
Ozer EJ, Best SR, Lipsey TL, Weiss DS. Predictors of posttraumatic stress disorder and symptoms in adults: A meta-analysis. Psychological Bulletin. 2003;129:52-73. [pmid: 12555794].
Pae CU, Lim HK, Peindl K, Ajwani N, Serretti A, Patkar AA, et al. The atypical antipsychotics olanzapine and risperidone in the treatment of posttraumatic stress disorder: A meta-analysis of randomized, double-blind, placebo-controlled clinical trials. International Clinical Psychopharmacology. 2008;23:1-8. [pmid: 18090502].
Palinkas L, Downs M, Patterson J, Russell J. Social, cultural, and psychological impacts of the Exxon Valdez oil spill. Human Organization. 1993;52:1-13.
Panagioti M, Gooding P, Tarrier N. Post-traumatic stress disorder and suicidal behavior: A narrative review. Clinical Psychology Review. 2009;29:471-482. [pmid: 19539412].
Pandya A. Group and family interventions. Stoddard FJ Jr, Pandya A, Katz CL, editors. Disaster psychiatry: Readiness, evaluation, and treatment. 2011:213-226. Arlington, VA. American Psychiatric Publishing, Inc.
Paranjape A, Liebschutz J. STaT: A three-question screen for intimate partner violence. Journal of Women’s Health (Larchment). 2003;12:233-239.
Pastor LH. Culture as examining the causes and consequences of collective trauma. Psychiatric Annals. 2004;34:616-622.
Paulson DS, Krippner S. 2007. Haunted by combat: Understanding PTSD in war veterans including women, reservists, and those coming back from Iraq. Westport, CT. Praeger. Security International.
Paunovic N, Öst LG. Cognitive–behavior therapy vs exposure therapy in the treatment of PTSD in refugees. Behaviour Research and Therapy. 2001;39:1183-1197. [pmid: 11579988].
Pearlman LA, Courtois CA. Clinical applications of the attachment framework: Relational treatment of complex trauma. Journal of Traumatic Stress. 2005;18:449-459. [pmid: 16281242].
Pearlman LA, Saakvitne KW. 1995. Trauma and the therapist: Countertransference and vicarious traumatization in psychotherapy with incest survivors. New York. W. W. Norton.
Peddle N. Assessing trauma impact, recovery, and resiliency in refugees of war. Journal of Aggression, Maltreatment & Trauma. 2007;14:185-204.
Peebles MJ. Posttraumatic stress disorder: A historical perspective on diagnosis and treatment. Bulletin of the Menninger Clinic. 1989;53:274-286. [pmid: 2655791].
Peirce JM, Burke CK, Stoller KB, Neufeld KJ, Brooner RK. Assessing traumatic event exposure: Comparing the Traumatic Life Events Questionnaire to the Structured Clinical Interview for DSM-IV. Psychological Assessment. 2009;21:210-218. [pmid: 19485675].
Peirce JM, Kindbom KA, Waesche MC, Yuscavage ASE, Brooner RK. Posttraumatic stress disorder, gender, and problem profiles in substance dependent patients. Substance Use & Misuse. 2008;43:596-611. [pmid: 18393079].
Peller AJ, Najavits LM, Nelson SE, LaBrie RA, Shaffer HJ. PTSD among a treatment sample of repeat DUI offenders. Journal of Traumatic Stress. 2010;23:468-473. [pmid: 20690170].
Peltan JR, Cellucci T. Childhood sexual abuse and substance abuse treatment utilization among substance-dependent incarcerated women. Journal of Substance Abuse Treatment. 2011;41:215-224. [pmid: 21550199].
Penning R, Veldstra JL, Daamen AP, Olivier B, Verster JC. Drugs of abuse, driving and traffic safety. Current Drug Abuse Reviews. 2010;3:23-32. [pmid: 20088818].
Peres JFP, Newberg AB, Mercante JP, Simão M, Albuquerque VE, Peres MJP, et al. Cerebral blood flow changes during retrieval of traumatic memories before and after psychotherapy: A SPECT study. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2007;37:1481-1491.
Perez Benitez CI, Yen S, Shea MT, Edelen MO, Markowitz JC, McGlashan TH, et al. Ethnicity in trauma and psychiatric disorders: Findings from the collaborative longitudinal study of personality disorders. Journal of Clinical Psychology. 2010;66:583-598. [pmid: 20455250].
Perilla JL, Norris FH, Lavizzo EA. Ethnicity, culture, and disaster response: Identifying and explaining ethnic differences in PTSD six months after Hurricane Andrew. Journal of Social and Clinical Psychology. 2002;21:20-45.
Peterlin BL, Rosso AL, Sheftell FD, Libon DJ, Mossey JM, Merikangas KR. Post-traumatic stress disorder, drug abuse and migraine: New findings from the National Comorbidity Survey Replication (NCS–R). Cephalalgia. 2011;31:235-244. [pmid: 20813779].
Petersilia JR. Crime victims with developmental disabilities: A review essay. Criminal Justice and Behavior. 2001;28:655-694.
Pfefferbaum BJ, Reissman DB, Pfefferbaum RL, Klomp RW, Gurwitch RH. Building resilience to mass trauma events. Doll LS, Bonzo SE, Mercy JA, Sleet DA, editors. Handbook of injury and violence prevention. 2007:347-358. New York. Springer Publishing Science + Business Media.
Pfeiffer PN, Ganoczy D, Ilgen M, Zivin K, Valenstein M. Comorbid anxiety as a suicide risk factor among depressed veterans. Depression and Anxiety. 2009;26:752-757. [pmid: 19544314].
Phillips CJ, Leardmann CA, Gumbs GR, Smith B. Risk factors for posttraumatic stress disorder among deployed US male marines. BMC Psychiatry. 2010;10:52. [pmid: 20579379].
Phoenix BJ. Psychoeducation for survivors of trauma. Perspectives in Psychiatric Care. 2007;43:123-131. [pmid: 17576305].
Picken A, Tarrier N. Trauma and comorbid posttraumatic stress disorder in individuals with schizophrenia and substance abuse. Comprehensive Psychiatry. 2011;52:490-497. [pmid: 21193183].
Pickering RP, Goldstein RB, Hasin DS, Blanco C, Smith SM, Huang B, et al. Temporal relationships between overweight and obesity and DSM-IV substance use, mood, and anxiety disorders: Results from a prospective study, the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Clinical Psychiatry. 2011;72:1494-1502. [pmid: 21457678].
Pico-Alfonso MA. Psychological intimate partner violence: the major predictor of posttraumatic stress disorder in abused women. Neuroscience and Biobehavioral Reviews. 2005;29:181-193. [pmid: 15652265].
Piefke M, Pestinger M, Arin T, Kohl B, Kastrau F, Schnitker R, et al. The neurofunctional mechanisms of traumatic and non-traumatic memory in patients with acute PTSD following accident trauma. Neurocase. 2007;13:342-357. [pmid: 18781433].
Pietrzak RH, Goldstein MB, Malley JC, Rivers AJ, Johnson DC, Southwick SM. Risk and protective factors associated with suicidal ideation in veterans of Operations Enduring Freedom and Iraqi Freedom. Journal of Affective Disorders. 2010;123:102-107. [pmid: 19819559].
Pietrzak RH, Goldstein RB, Southwick SM, Grant BF. Physical health conditions associated with posttraumatic stress disorder in U.S. older adults: Results from Wave 2 of the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of the American Geriatrics Society. 2012;60:296-303. [pmid: 22283516].
Pietrzak RH, Goldstein RB, Southwick SM, Grant BF. Personality disorders associated with full and partial posttraumatic stress disorder in the U.S. population: Results from Wave 2 of the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Psychiatric Research. 2011;45:678-686. [pmid: 20950823].
Pietrzak RH, Goldstein RB, Southwick SM, Grant BF. Prevalence and Axis I comorbidity of full and partial posttraumatic stress disorder in the United States: Results from Wave 2 of the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Anxiety Disorders. 2011;25:456-465. [pmid: 21168991].
Pietrzak RH, Johnson DC, Goldstein MB, Malley JC, Rivers AJ, Morgan CA, et al. Psychosocial buffers of traumatic stress, depressive symptoms, and psychosocial difficulties in veterans of Operations Enduring Freedom and Iraqi Freedom: The role of resilience, unit support, and postdeployment social support. Journal of Special Operations Medicine. 2009;9:74-78. [pmid: 19739480].
Plummer SB, Findley PA. Women with disabilities’ experience with physical and sexual abuse. Trauma, Violence, & Abuse. 2012;13:15-29.
Pole N, Best SR, Metzler T, Marmar CR. Why are Hispanics at greater risk for PTSD?. Cultural Diversity and Ethnic Minority Psychology. 2005;11:144-161. [pmid: 15884985].
Pole N, Best SR, Weiss DS, Metzler T, Liberman AM, Fagan J, et al. Effects of gender and ethnicity on duty-related posttraumatic stress symptoms among urban police officers. Journal of Nervous & Mental Disease. 2003;189:442-448. [pmid: 11504321].
Pole N, Gone JP, Kulkarni M. Posttraumatic stress disorder among ethnoracial minorities in the United States. Clinical Psychology: Science and Practice. 2008;15:35-61.
Polinder S, Haagsma JA, Belt E, Lyons RA, Erasmus V, Lund J, et al. A systematic review of studies measuring health-related quality of life of general injury populations. BMC Public Health. 2010;10:783. [pmid: 21182775].
Polinder S, Haagsma JA, Lyons RA, Gabbe BJ, Ameratunga S, Cryer C, et al. Measuring the population burden of fatal and nonfatal injury. Epidemiologic Reviews. 2012;34:17-31. [pmid: 22113244].
Polusny MA, Erbes CR, Murdoch M, Arbisi PA, Thuras P, Rath MB. Prospective risk factors for new-onset post-traumatic stress disorder in National Guard soldiers deployed to Iraq. Psychological Medicine. 2011;41:687-698. [pmid: 21144108].
Polusny MA, Ries BJ, Schultz JR, Calhoun P, Clemensen L, Johnsen IR. PTSD symptom clusters associated with physical health and health care utilization in rural primary care patients exposed to natural disaster. Journal of Traumatic Stress. 2008;21:75-82. [pmid: 18302175].
Ponniah K, Hollon SD. Empirically supported psychological treatments for adult acute stress disorder and posttraumatic stress disorder: A review. Depression and Anxiety. 2009;26:1086-1109. [pmid: 19957280].
Pope KS, Brown LS. 1996. Recovered memories of abuse: Assessment, therapy, forensics. Washington, DC. American Psychological Association.
Possemato K, Ouimette P, Knowlton P. A brief self-guided telehealth intervention for post-traumatic stress disorder in combat veterans: A pilot study. Journal of Telemedicine and Telecare. 2011;17:245-250. [pmid: 21636687].
Poulin MJ, Silver RC, Gil-Rivas V, Holman EA, McIntosh DN. Finding social benefits after a collective trauma: perceiving societal changes and well–being following 9/11. Journal of Traumatic Stress. 2009;22:81-90. [pmid: 19283834].
Powers MB, Halpern JM, Ferenschak MP, Gillihan SJ, Foa EB. A meta-analytic review of prolonged exposure for posttraumatic stress disorder. Clinical Psychology Review. 2010;30:635-641. [pmid: 20546985].
Pratchett LC, Pelcovitz MR, Yehuda R. Trauma and violence: Are women the weaker sex?. Psychiatric Clinics of North America. 2010;33:465-474. [pmid: 20385347].
Prescott L, Soares P, Konnath K, Bassuk E. 2008. A long journey home: A guide for creating trauma-informed services for mothers and children experiencing homelessness Draft. Rockville, MD. Center for Mental Health Services, Substance Abuse and Mental Health Services Administration and the Daniels Fund, National Child Traumatic Stress Network, and the W. K Kellogg Foundation.
Prigerson HG, Maciejewski PK, Rosenheck RA. Population attributable fractions of psychiatric disorders and behavioral outcomes associated with combat exposure among US men. American Journal of Public Health. 2002;92:59-63. [pmid: 11772762].
Prins A, Cimpean D, Schnurr PP. Treatment in primary care settings. Treatment of posttraumatic stress disorder in special populations: A cognitive restructuring program. 2009:301-314. Washington, DC. American Psychological Association.
Prins A, Ouimette P, Kimerling R, Cameron RP, Hugelshofer DS, Shaw-Hegwer J, et al. The Primary Care PTSD Screen (PC–PTSD): Development and operating characteristics. Primary Care Psychiatry. 2004;9:9-14.
Provencher MD, Hawke LD, Thienot E. Psychotherapies for comorbid anxiety in bipolar spectrum disorders. Journal of Affective Disorders. 2011;133:371-380. [pmid: 21093062].
PsychologyTools.org. 2012. Checklist for Better Sleep. UK. Psychology Tools.org.
Ptasznik A. No safe haven: Restraints reform targets traumatizing hospital practices. Cross Currents. 2009;12(3).
Pulay AJ, Stinson FS, Dawson DA, Goldstein RB, Chou SP, Huang B, et al. Prevalence, correlates, disability, and comorbidity of DSM-IV schizotypal personality disorder: Results From the Wave 2 National Epidemiologic Survey on Alcohol and Related Conditions. The Primary Care Companion to The Journal of Clinical Psychiatry. 2009;11:53-67.
Pyari TT, Kutty RV, Sarma PS. Risk factors of post-traumatic stress disorder in tsunami survivors of Kanyakumari District, Tamil Nadu, India. Indian Journal of Psychiatry. 2012;54:48-53. [pmid: 22556437].
Pynoos RS, Steinberg AM, Schreiber MD, Brymer MJ. Children and families: A new framework for preparedness and response to danger, terrorism, and trauma. Schein LA, Spitz HI, Burlingame GM, Muskin PR, editors. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:83-112. New York. Haworth Press.
Quarantini LC, Miranda-Scippa A, Nery-Fernandes F, Andrade–Nascimento M, Galvão–de–Almeida A, Guimarães JL, et al. The impact of comorbid posttraumatic stress disorder on bipolar disorder patients. Journal of Affective Disorders. 2010;123:71-76. [pmid: 19732957].
Quosh C, Gergen KJ. Constructing trauma and its treatment: Knowledge, power and resistance. Sugiman T, Gergen KJ, Wagner W, Yamada Y, editors. Meaning in action: Constructions, narratives, and representations. 2008:97-111. New York. Springer Publishing Science + Business Media.
Qureshi SU, Pyne JM, Magruder KM, Schulz PE, Kunik ME. The link between post-traumatic stress disorder and physical comorbidities: A systematic review. Psychiatric Quarterly. 2009;80:87-97. [pmid: 19291401].
Racanelli C. Attachment and compassion fatigue among American and Israeli mental health clinicians working with traumatized victims of terrorism. International Journal of Emergency Mental Health. 2005;7:115-124. [pmid: 16107043].
Rachamim L, Nacasch N, Shafran N, Tzur D, Gilboa-Schechtman E. Exposure-based therapy for post-traumatic stress disorder in children and adults. Israel Journal of Psychiatry and Related Sciences. 2009;46:274-281. [pmid: 20635775].
Rakofsky JJ, Dunlop BW. Treating nonspecific anxiety and anxiety disorders in patients with bipolar disorder: A review. Journal of Clinical Psychiatry. 2011;72:81-90. [pmid: 21208580].
Rand MR, obinson JF. 2012. Criminal victimization in the United States, 2008 – Statistical tables. Washington, DC. Bureau of Justice Statistics.
Raphael B, Wooding S. Group intervention for the prevention and treatment of acute initial stress reactions in civilians. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:481-503. New York. Haworth Press.
Rasmussen B. The effects of trauma treatment on the therapist. Ringel S, Brandell JR, editors. Trauma: Contemporary directions in theory, practice, and research. 2012:223-246. Thousand Oaks, CA. Sage Publications.
Rasmussen T, Bloomenfeld J. Focus: Healping to heal the scars: What does trauma-informed look like?. Cross Currents. 2009;12(3).
Rauch SA, Grunfeld TE, Yadin E, Cahill SP, Hembree E, Foa EB. Changes in reported physical health symptoms and social function with prolonged exposure therapy for chronic posttraumatic stress disorder. Depression and Anxiety. 2009;26:732-738. [pmid: 18781660].
Ravindran LN, Stein MB. Pharmacotherapy of PTSD: Premises, principles, and priorities. Brain Research. 2009;1293:24-39. [pmid: 19332035].
Ravindran LN, Stein MB. Pharmacotherapy of post-traumatic stress disorder. Current Topics in Behavioral Neurosciences. 2010;2:505-525. [pmid: 21309124].
Ravindran LN, Stein MB, Ravindran AV. Pharmacotherapy of PTSD: An evidence-based review. Sher L, Vilens A, editors. Neurobiology of post-traumatic stress disorder. 2010:271-290. New York. Nova Biomedical.
Ray LA, Capone C, Sheets E, Young D, Chelminski I, Zimmerman M. Posttraumatic stress disorder with and without alcohol use disorders: Diagnostic and clinical correlates in a psychiatric sample. Psychiatry Research. 2009;170:278-281. [pmid: 19900714].
Razza NJ, Tomasulo DJ, Sobsey D. Group psychotherapy for trauma-related disorders in people with intellectual disabilities. Advances in Mental Health and Intellectual Disabilities. 2011;5:40-45.
Read J, Hammersley P. Child sexual abuse and schizophrenia. British Journal of Psychiatry. 2005;186:76. [pmid: 15690589].
Read JP, Bollinger AR, Sharkansky E. Assessment of comorbid substance use disorder and posttraumatic stress disorder. Ouimette P, Brown PJ, editors. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. 2003:111-125. Washington, DC. American Psychological Association.
Read J, Agar K, Argyle N, Aderhold V. Sexual and physical abuse during childhood and adulthood as predictors of hallucinations, delusions and thought disorder. Psychology and Psychotherapy: Theory, Research and Practice. 2003;76:1-22.
Read J, van Os J, Morrison AP, Ross CA. Childhood trauma, psychosis and schizophrenia: A literature review with theoretical and clinical implications. Acta Psychiatrica Scandinavica. 2005;112:330-350. [pmid: 16223421].
Ready DJ, Thomas KR, Worley V, Backscheider AG, Harvey LA, Baltzell D, et al. A field test of group based exposure therapy with 102 veterans with war-related posttraumatic stress disorder. Journal of Traumatic Stress. 2008;21:150-157. [pmid: 18404634].
Reddy MK, Polusny MA, Murdoch M. On counterbalancing of symptom–reporting in trauma surveys. Psychological Reports. 2009;105:1154-1158. [pmid: 20229918].
Rees B. Overview of outcome data of potential meditation training for soldier resilience. Military Medicine. 2011;176:1232-1242. [pmid: 22165650].
Regel S, Joseph S, Dyregrov A. Psychological debriefing in cross-cultural contexts: Ten implications for practice. Int.J Emerg Ment Health. 2007;9:37-45. [pmid: 17523374].
Reiland S, Lauterbach D. Effects of trauma and religiosity on self-esteem. Psychological Reports. 2008;102:779-790. [pmid: 18763449].
Relapse prevention: Maintenance strategies in the treatment of addictive behaviors. 2005. 2nd ed. New York. Guilford Press.
Renshaw KD. An integrated model of risk and protective factors for post-deployment PTSD symptoms in OEF/OIF era combat veterans. Journal of Affective Disorders. 2011;128:321-326. [pmid: 20692705].
Renshaw KD, Blais RK, Caska CM. Distress in spouses of combat veterans with PTSD: The importance of interpersonally based cognitions and behaviors. Wadsworth SM, Riggs D, editors. Risk and resilience in US military families. 2011:69-84. New York. Springer Publishing Science + Business Media.
Renshaw KD, Rodrigues CS, Jones DH. Psychological symptoms and marital satisfaction in spouses of Operation Iraqi Freedom veterans: Relationships with spouses’ perceptions of veterans’ experiences and symptoms. Journal of Family Psychology. 2008;22:586-594. [pmid: 18729672].
Resick PA. Cognitive therapy for posttraumatic stress disorder. Journal of Cognitive Psychotherapy: An International Quarterly. 2001;15:321-329.
Resick PA, Schnicke MK. Cognitive processing therapy for sexual assault victims. Journal of Consulting and Clinical Psychology. 1992;60:748-756. [pmid: 1401390].
Resick PA, Schnicke MK. 1993. Cognitive processing therapy for rape victims: A treatment manual. Newbury Park, CA. Sage Publications.
Resick PA, Galovski TE, O’Brien UM, Scher CD, Clum GA, Young-Xu Y. A randomized clinical trial to dismantle components of cognitive processing therapy for posttraumatic stress disorder in female victims of interpersonal violence. Journal of Consulting and Clinical Psychology. 2008;76:243-258. [pmid: 18377121].
Resick PA, Nishith P, Griffin MG. How well does cognitive–behavioral therapy treat symptoms of complex PTSD? An examination of child sexual abuse survivors within a clinical trial. CNS Spectrums. 2003;8:340-355. [pmid: 12766690].
Resick PA, Nishith P, Weaver TL, Astin MC, Feuer CA. A comparison of cognitive–processing therapy with prolonged exposure and a waiting condition for the treatment of chronic posttraumatic stress disorder in female rape victims. Journal of Consulting & Clinical Psychology. 2002;70:867-879. [pmid: 12182270].
Resick PA, Williams LF, Suvak MK, Monson CM, Gradus JL. Long-term outcomes of cognitive–behavioral treatments for posttraumatic stress disorder among female rape survivors. Journal of Consulting and Clinical Psychology. 2012;80:201-210. [pmid: 22182261].
Resnick HS, Acierno R, Amstadter AB, Self-Brown S, Kilpatrick DG. An acute post-sexual assault intervention to prevent drug abuse: Updated findings. Addict Behav. 2007;32:2032-2045. [pmid: 17275198].
Resnick HS, Kilpatrick DG, Dansky BS, Saunders BE, Best CL. Prevalence of civilian trauma and posttraumatic stress disorder in a representative national sample of women. Journal of Consulting and Clinical Psychology. 1993;61:984-991. [pmid: 8113499].
Resnick SG, Bond GR, Mueser KT. Trauma and posttraumatic stress disorder in people with schizophrenia. Journal of Abnormal Psychology. 2003;112:415-423. [pmid: 12943020].
Reynolds M, Mezey G, Chapman M, Wheeler M, Drummond C, Baldacchino A. Co-morbid post-traumatic stress disorder in a substance misusing clinical population. Drug and Alcohol Dependence. 2005;77:251-258. [pmid: 15734225].
Reyome ND. Childhood emotional maltreatment and later intimate relationships: Themes from the empirical literature. Journal of Aggression, Maltreatment & Trauma. 2010;19:224-242.
Rhatigan DL, Moore TM, Street AE. Reflections on partner violence. Journal of Interpersonal Violence. 2005;20:82-88. [pmid: 15618564].
Richardson JD, Elhai JD, Pedlar DJ. Association of PTSD and depression with medical and specialist care utilization in modern peacekeeping veterans in Canada with health-related disabilities. Journal of Clinical Psychiatry. 2006;67:1240-1245. [pmid: 16965202].
Richardson JI. 2001. Guidebook on vicarious trauma: Recommended solutions for anti-violence workers. Ottawa, Ontario. Health Canada.
Riggs DS, Monson CM, Glynn SM, Canterino J. Couple and family therapy for adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:458-478. New York. Guilford Press.
Riggs DS, Rukstalis M, Volpicelli JR, Kalmanson D, Foa EB. Demographic and social adjustment characteristics of patients with comorbid posttraumatic stress disorder and alcohol dependence: potential pitfalls to PTSD treatment. Addictive Behaviors. 2003;28:1717-1730. [pmid: 14656555].
Risk and resilience in US military families. 2011. New York. Springer Publishing Science + Business Media.
Roberts AL, Austin SB, Corliss HL, Vandermorris AK, Koenen KC. Pervasive trauma exposure among US sexual orientation minority adults and risk of posttraumatic stress disorder. American Journal of Public Health. 2010;100:2433-2441. [pmid: 20395586].
Roberts AL, Gilman SE, Breslau J, Breslau N, Koenen KC. Race/ethnic differences in exposure to traumatic events, development of post-traumatic stress disorder, and treatment-seeking for post-traumatic stress disorder in the United States. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2011;41:71-83.
Roberts AL, McLaughlin KA, Conron KJ, Koenen KC. Adulthood stressors, history of childhood adversity, and risk of perpetration of intimate partner violence. American Journal of Preventive Medicine. 2011;40:128-138. [pmid: 21238860].
Roberts NP, Kitchiner NJ, Kenardy J, Bisson J. Multiple session early psychological interventions for the prevention of post-traumatic stress disorder. Cochrane Database of Systematic Reviews. 2009:CD006869. [pmid: 19588408].
Roberts NP, Kitchiner NJ, Kenardy J, Bisson JI. Systematic review and meta-analysis of multiple-session early interventions following traumatic events. American Journal of Psychiatry. 2009;166:293-301. [pmid: 19188285].
Roberts NP, Kitchiner NJ, Kenardy J, Bisson JI. Early psychological interventions to treat acute traumatic stress symptoms. Cochrane Database of Systematic Reviews. 2010:CD007944. [pmid: 20238359].
Robinaugh DJ, McNally RJ. Trauma centrality and PTSD symptom severity in adult survivors of childhood sexual abuse. Journal of Traumatic Stress. 2011;24:483-486. [pmid: 21793046].
Robjant K, Fazel M. The emerging evidence for narrative exposure therapy: A review. Clinical Psychology Review. 2010;30:1030-1039. [pmid: 20832922].
Rohde P, Ichikawa L, Simon GE, Ludman EJ, Linde Jongh A, Jeffery RW, et al. Associations of child sexual and physical abuse with obesity and depression in middle–aged women. Child Abuse & Neglect. 2008;32:878-887. [pmid: 18945487].
Roht-Arriaza N. Punishment, redress, and pardon: Theoretical and psychological approaches. Roht-Arriaza N, editor. Impunity and human rights in international law and practice. 1995:13-23. Oxford, England. Oxford University Press.
Roman PM, Johnson JA. 2002. National Treatment Center Study summary report: Private treatment centers. Athens, GA. Institute for Behavioral Research, University of Georgia.
Rosen GM, Frueh BC. 2010. Clinician’s guide to posttraumatic stress disorder. Hoboken, NJ. John Wiley and Sons, Inc.
Rosenbaum S, Nguyen D, Lenehan T, Tiedemann A, van der Ploeg HP, Sherrington C. Exercise augmentation compared to usual care for post traumatic stress disorder: A randomised controlled trial (the REAP study: Randomised Exercise Augmentation for PTSD). BMC Psychiatry. 2011;11.
Rosenberg L. 2011. 2011 Letters: Trauma-informed care: A call to arms. Washington, DC. National Council for Community Behavioral Healthcare.
Rosenberg SD, Mueser KT. Trauma and posttraumatic stress syndromes. Mueser KT, Jeste DV, editors. Clinical handbook of schizophrenia. 2008:447-458. New York. Guilford Press.
Rosenberg SD, Lu W, Mueser KT, Jankowski MK, Cournos F. Correlates of adverse childhood events among adults with schizophrenia spectrum disorders. Psychiatric Services. 2007;58:245-253. [pmid: 17287383].
Rosenberg SD, Mueser KT, Friedman MJ, Gorman PG, Drake RE, Vidaver RM, et al. Developing effective treatments for posttraumatic disorders among people with severe mental illness. Psychiatric Services. 2001;52:1453-1461. [pmid: 11684740].
Rosenheck R, Fontana A. Race and outcome of treatment for veterans suffering from PTSD. Journal of Traumatic Stress. 1996;9:343-351. [pmid: 8731552].
Rosenthal BS, Wilson WC. The association of ecological variables and psychological distress with exposure to community violence among adolescents. Adolescence. 2003;38:459-479. [pmid: 14768992].
Rosenthal JZ, Grosswald S, Ross R, Rosenthal N. Effects of transcendental meditation in veterans of Operation Enduring Freedom and Operation Iraqi Freedom with posttraumatic stress disorder: A pilot study. Military Medicine. 2011;176:626-630. [pmid: 21702378].
Rossen LM, Pollack KM, Canham-Chervak M, Canada S, Baker SP. Motor vehicle crashes among active duty U.S. Army personnel, 1999 to 2006. Military Medicine. 2011;176:1019-1026. [pmid: 21987960].
Rothbaum BO. Another perspective on exposure therapy for PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:211-215. Chichester, UK. John Wiley and Sons, Inc.
Rothbaum BO, Davidson JR, Stein DJ, Pedersen R, Musgnung J, Tian XW, et al. A pooled analysis of gender and trauma-type effects on responsiveness to treatment of PTSD with venlafaxine extended release or placebo. Journal of Clinical Psychiatry. 2008;69:1529-1539. [pmid: 19192435].
Rothbaum BO, Meadows EA, Resick P, Foy DW. Cognitive–behavioral therapy. Foa EB, Keane TM, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2000:60-83. New York. Guilford Press.
Rothman EF, Exner D, Baughman AL. The prevalence of sexual assault against people who identify as gay, lesbian, or bisexual in the United States: A systematic review. Trauma, Violence, & Abuse. 2011;12:55-66.
Roy-Byrne PP, Russo J, Michelson E, Zatzick D, Pitman RK, Berliner L. Risk factors and outcome in ambulatory assault victims presenting to the acute emergency department setting: implications for secondary prevention studies in PTSD. Depression and Anxiety. 2004;19:77-84. [pmid: 15022142].
Royle L, Keenan P, Farrell D. Issues of stigma for first responders accessing support for post traumatic stress. International Journal of Emergency Mental Health. 2009;11:79-85. [pmid: 19927494].
Rubin DC, Berntsen D, Bohni MK. A memory-based model of posttraumatic stress disorder: Evaluating basic assumptions underlying the PTSD diagnosis. Psychological Review. 2008;115:985-1011. [pmid: 18954211].
Ruef AM, Litz BT, Schlenger WE. Hispanic ethnicity and risk for combat-related posttraumatic stress disorder. Cultural Diversity and Ethnic Minority Psychology. 2000;6:235-251. [pmid: 10938633].
Rush AJ, Zimmerman M, Wisniewski SR, Fava M, Hollon SD, Warden D, et al. Comorbid psychiatric disorders in depressed outpatients: Demographic and clinical features. Journal of Affective Disorders. 2005;87:43-55. [pmid: 15894381].
Rush B, Koegl CJ. Prevalence and profile of people with co-occurring mental and substance use disorders within a comprehensive mental health system. Canadian Journal of Psychiatry. 2008;53:810-821.
Russell MC. War-related medically unexplained symptoms, prevalence, and treatment: Utilizing EMDR within the armed services. Journal of EMDR Practice and Research. 2008;2:212-225.
Ruzek JI. Models of early intervention following mass violence and other trauma. Interventions following mass violence and disasters: Strategies for mental health practice. 2006:16-34. New York. Guilford Press.
Ruzek J, Walser RD, Naugle AE, Litz B, Mennin DS, Polusny MA, et al. Cognitive–behavioral psychology: Implications for disaster and terrorism response. Prehospital and Disaster Medicine. 2008;23:397-410. [pmid: 19189609].
Saakvitne KW, Pearlman LA. & Traumatic Stress Institute/Center for Adult & Adolescent Psychotherapy. 1996. Transforming the pain: A workbook on vicarious traumatization. 1st ed. New York. W.W. Norton.
Sacks JY, McKendrick K, Banks S. The impact of early trauma and abuse on residential substance abuse treatment outcomes for women. Journal of Substance Abuse Treatment. 2008;34:90-100. [pmid: 17574799].
Sacks S, McKendrick K, Sacks JY, Banks S, Harle M. Enhanced outpatient treatment for co-occurring disorders: Main outcomes. Journal of Substance Abuse Treatment. 2008;34:48-60. [pmid: 17574795].
Sadler AG, Booth BM, Cook BL, Doebbeling BN. Factors associated with women’s risk of rape in the military environment. American Journal of Industrial Medicine. 2003;43:262-273. [pmid: 12594773].
Sala T, Cox BJ, Sareen J. Anxiety disorders and physical illness comorbidity: An overview. Anxiety in health behaviors and physical illness. 2008:131-154. New York. Springer Publishing Science + Business Media.
Salasin S. Sine qua non for public health. National Council Magazine. 2011;18.
Salyers MP, Evans LJ, Bond GR, Meyer PS. Barriers to assessment and treatment of posttraumatic stress disorder and other trauma-related problems in people with severe mental illness: Clinician perspectives. Community Mental Health Journal. 2004;40:17-31. [pmid: 15077726].
San Diego Trauma Informed Guide Team. 2012. Are you asking the right questions? A client centered approach. San Diego, CA. San Diego Trauma Informed Guide Team.
Sandoval J, Scott AN, Padilla I. Crisis counseling: An overview. Psychology in the Schools. 2009;46:246-256.
Santa Mina EE, Gallop RM. Childhood sexual and physical abuse and adult self-harm and suicidal behaviour: A literature review. Canadian Journal of Psychiatry. 1998;43:793-800.
Santos MR, Russo J, Aisenberg G, Uehara E, Ghesquiere A, Zatzick DF. Ethnic/racial diversity and posttraumatic distress in the acute care medical setting. Psychiatry. 2008;71:234-245. [pmid: 18834274].
Sarapas C, Cai G, Bierer LM, Golier JA, Galea S, Ising M, et al. Genetic markers for PTSD risk and resilience among survivors of the World Trade Center attacks. Disease Markers. 2011;30:101-110. [pmid: 21508514].
Sartor CE, McCutcheon VV, Pommer NE, Nelson EC, Grant JD, Duncan AE, et al. Common genetic and environmental contributions to post-traumatic stress disorder and alcohol dependence in young women. Psychological Medicine. 2011;41:1497-1505. [pmid: 21054919].
Sautter FJ, Armelie AP, Glynn SM, Wielt DB. The development of a couple-based treatment for PTSD in returning veterans. Professional Psychology: Research and Practice. 2011;42:63-69.
Sautter FJ, Glynn SM, Thompson KE, Franklin L, Han X. A couple-based approach to the reduction of PTSD avoidance symptoms: Preliminary findings. Journal of Marital and Family Therapy. 2009;35:343-349. [pmid: 19522786].
Savage A, Quiros L, Dodd SJ, Bonavota D. Building trauma informed practice: Appreciating the impact of trauma in the lives of women with substance abuse and mental health problems. Journal of Social Work Practice in the Addictions. 2007;7:91-116.
Savoca E, Rosenheck R. The civilian labor market experiences of Vietnam–era veterans: The influence of psychiatric disorders. Journal of Mental Health Policy and Economics. 2000;3:199-207. [pmid: 11967456].
Saxon AJ, Davis TM, Sloan KL, McKnight KM, Jeammet P, Kivlahan DR. Trauma, symptoms of posttraumatic stress disorder, and associated problems among incarcerated veterans. Psychiatric Services. 2001;52:959-964. [pmid: 11433115].
Sayed AM, Galea S. Challenges and future horizons in epedemiological research into PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:75-81. Chichester, UK. John Wiley and Sons, Inc.
Sayer NA, Carlson KF, Schnurr PP. Assessment of functioning and disability. Benedek DM, Wynn GH, editors. Clinical manual for management of PTSD. 2011:255-287. Arlington, VA, US. American Psychiatric Publishing, Inc.
Sayer NA, Noorbaloochi S, Frazier P, Carlson K, Gravely A, Murdoch M. Reintegration problems and treatment interests among Iraq and Afghanistan combat veterans receiving VA medical care. Psychiatric Services. 2010;61:589-597. [pmid: 20513682].
Schacht L, Pandiani JA, Banks SM. Access to community mental health services: A study of adult victims of trauma. Best Practices in Mental Health: An International Journal. 2007;3:1-8.
Schafer I, Fisher HL. Childhood trauma and posttraumatic stress disorder in patients with psychosis: clinical challenges and emerging treatments. Current Opinion in Psychiatry. 2011;24.
Schafer I, Morgan C, Demjaha A, Morgan K, Dazzan P, Fearon P, et al. Assessment of posttraumatic symptoms in patients with first-episode psychosis. Journal of Nervous and Mental Disease. 2011;199:896-898. [pmid: 22048144].
Schauben LJ, Frazier PA. Vicarious trauma: The effects on female counselors of working with sexual violence survivors. Psychology of Women Quarterly. 1995;19:49-64.
Schechter DS, Willheim E. The effects of violent experiences on infants and young children. Handbook of infant mental health. 3rd ed. 2009:197-213. New York. Guilford Press.
Schein LA, Spitz HI, Burlingame GM, Muskin PR. 2006. Psychological effects of catastrophic disasters: Group approaches to treatment. New York. Haworth Press.
Schneier FR, Neria Y, Pavlicova M, Hembree E, Suh EJ, Amsel L, et al. Combined prolonged exposure therapy and paroxetine for PTSD related to the World Trade Center attack: A randomized controlled trial. American Journal of Psychiatry. 2012;169:80-88. [pmid: 21908494].
Schnurr PP, Lunney CA. Work-related quality of life and posttraumatic stress disorder symptoms among female veterans. Womens Health Issues. 2011;21:S169-S175. [pmid: 21724137].
Schnurr PP, Friedman MJ, Engel CC, Foa EB, Shea MT, Chow BK, et al. Cognitive behavioral therapy for posttraumatic stress disorder in women: A randomized controlled trial. JAMA: The Journal of the American Medical Association. 2007;297:820-830. [pmid: 17327524].
Schnurr PP, Friedman MJ, Foy DW, Shea MT, Hsieh FY, Lavori PW, et al. Randomized trial of trauma-focused group therapy for posttraumatic stress disorder: Results from a Department of Veterans Affairs Cooperative Study. Archives of General Psychiatry. 2003;60:481-489. [pmid: 12742869].
Schnurr PP, Lunney CA, Bovin MJ, Marx BP. Posttraumatic stress disorder and quality of life: Extension of findings to veterans of the wars in Iraq and Afghanistan. Clinical Psychology Review. 2009;29:727-735. [pmid: 19744758].
Schnurr PP, Lunney CA, Sengupta A, Waelde LC. A descriptive analysis of PTSD chronicity in Vietnam veterans. Journal of Traumatic Stress. 2003;16:545-553. [pmid: 14690351].
Schönenberg M, Reichwald U, Domes G, Badke A, Hautzinger M. Effects of peritraumatic ketamine medication on early and sustained posttraumatic stress symptoms in moderately injured accident victims. Psychopharmacology (Berl). 2005;182:420-425. [pmid: 16012867].
Schönenberg M, Reichwald U, Domes G, Badke A, Hautzinger M. Ketamine aggravates symptoms of acute stress disorder in a naturalistic sample of accident victims. Journal of Psychopharmacology. 2008;22:493-497. [pmid: 18208917].
Schottenbauer MA, Glass CR, Arnkoff DB, Gray SH. Contributions of psychodynamic approaches to treatment of PTSD and trauma: A review of the empirical treatment and psychopathology literature. Psychiatry. 2008;71:13-34. [pmid: 18377203].
Schottenbauer MA, Glass CR, Arnkoff DB, Tendick V, Gray SH. Nonresponse and dropout rates in outcome studies on PTSD: review and methodological considerations. Psychiatry. 2008;71:134-168. [pmid: 18573035].
Schredl M, Reinhard I. Gender differences in nightmare frequency: A meta-analysis. Sleep Medicine Reviews. 2011;15:115-121. [pmid: 20817509].
Schubert CC, Punamäki RL. Mental health among torture survivors: Cultural background, refugee status and gender. Nordic Journal of Psychiatry. 2011;65:175-182. [pmid: 20854222].
Schulz PM, Marovic-Johnson D, Huber LC. Cognitive–behavioral treatment of rape- and war-related posttraumatic stress disorder with a female, Bosnian refugee. Clinical Case Studies. 2006;5:191-208.
Schumm JA, Briggs-Phillips M, Hobfoll SE. Cumulative interpersonal traumas and social support as risk and resiliency factors in predicting PTSD and depression among inner-city women. Journal of Traumatic Stress. 2006;19:825-836. [pmid: 17195981].
Schwartz RC, Schwartz MF, Galperin L. Internal family systems therapy. Treating complex traumatic stress disorders: An evidence-based guide. 2009:353-370. New York. Guilford Press.
Schwartz S, Hoyte J, James T, Conoscenti L, Johnson R, Liebschutz J. Challenges to engaging Black male victims of community violence in healthcare research: Lessons learned from two studies. Psychological trauma: Theory, research, practice, and policy. 2010;2:54-62.
Schwartzbard R. 1997. On the scene report of the Missouri floods. Ronkonkoma, NY. American Academy of Experts in Traumatic Stress.
Schweitzer RD, Brough M, Vromans L, Asic-Kobe M. Mental health of newly arrived Burmese refugees in Australia: Contributions of pre-migration and post-migration experience. Australian and New Zealand Journal of Psychiatry. 2011;45:299-307. [pmid: 21303193].
Schweitzer R, Melville F, Steel Z, Lacherez P. Trauma, post-migration living difficulties, and social support as predictors of psychological adjustment in resettled Sudanese refugees. Australian and New Zealand Journal of Psychiatry. 2006;40:179-187. [pmid: 16476137].
Scott JC. 1990. Domination and the arts of resistance: Hidden transcripts. New Haven, CT. Yale University Press.
Scott WJ. PTSD in DSM-III: A case in the politics of diagnosis and disease. Social Problems. 1990;37:294-310.
Seal KH, Metzler TJ, Gima KS, Bertenthal D, Maguen S, Marmar CR. Trends and risk factors for mental health diagnoses among Iraq and Afghanistan veterans using Department of Veterans Affairs health care, 2002–2008. American Journal of Public Health. 2009;99:1651-1658. [pmid: 19608954].
Seal KH, Shi Y, Cohen G, Cohen BE, Maguen S, Krebs EE, et al. Association of mental health disorders with prescription opioids and high-risk opioid use in US veterans of Iraq and Afghanistan. JAMA. 2012;307:940-947. [pmid: 22396516].
Segal ZV, Williams JMG, Teasdale JD. 2002. Mindfulness-based cognitive therapy for depression: A new approach to preventing relapse. New York. Guilford Press.
Seidler GH, Wagner FE. Comparing the efficacy of EMDR and trauma-focused cognitive–behavioral therapy in the treatment of PTSD: A meta-analytic study. Psychological Medicine. 2006;36:1515-1522. [pmid: 16740177].
Seng JS, Kohn–Wood LP, McPherson MD, Sperlich M. Disparity in posttraumatic stress disorder diagnosis among African American pregnant women. Archives of Women’s Mental Health. 2011;14:295-306.
Seng JS, Low LK, Sperlich M, Ronis DL, Liberzon I. Post-traumatic stress disorder, child abuse history, birthweight and gestational age: A prospective cohort study. International Journal of Obstetrics and Gynaecology. 2011;118:1329-1339.
Sequeira H, Hollins S. Clinical effects of sexual abuse on people with learning disability: Critical literature review. British Journal of Psychiatry. 2003;182:13-19. [pmid: 12509313].
Sexton L. Vicarious traumatisation of counsellors and effects on their workplaces. British Journal of Guidance & Counselling. 1999;27:393-403.
Shah SA. Ethnomedical best practices for international psychosocial efforts in disaster and trauma. Wilson JP, Tang CS, editors. Cross-cultural assessment of psychological trauma and PTSD. 2007:51-64. New York. Springer Publishing Science + Business Media.
Shaikh Al, Arab A, Guedon-Moreau L, Ducrocq F, Molenda S, Duhem S, Salleron J, et al. 2012. Temporal analysis of heart rate variability as a predictor of post traumatic stress disorder in road traffic accidents survivors. Journal of Psychiatric Research.
Shalev AY, Ankri Y, Israeli-Shalev Y, Peleg T, Adessky R, Freedman S. Prevention of posttraumatic stress disorder by early treatment: results from the Jerusalem Trauma Outreach And Prevention study. Archives of General Psychiatry. 2012;69:166-176. [pmid: 21969418].
Shalev AY, Sahar T, Freedman S, Peri T, Glick N, Brandes D, et al. A prospective study of heart rate response following trauma and the subsequent development of posttraumatic stress disorder. Archives of General Psychiatry. 1998;55:553-559. [pmid: 9633675].
Shalev AY, Tuval-Mashiach R, Hadar H. Posttraumatic stress disorder as a result of mass trauma. Journal of Clinical Psychiatry, 65 Supplement. 2004;1:4-10.
Shapiro F. 2001. Eye movement desensitization and reprocessing (EMDR): Basic principles, protocols, and procedures. 2nd ed. New York. Guilford Press.
Sharpless BA, Barber JP. A clinician’s guide to PTSD treatments for returning veterans. Professional Psychology: Research and Practice. 2011;42:8-15.
Sharpley JG, Fear NT, Greenberg N, Jones M, Wessely S. Pre-deployment stress briefing: Does it have an effect?. Occupational Medicine. 2008;58:30-34. [pmid: 18032390].
Shaw JA, Espinel Z, Shultz JM. The context of trauma. Children: Stress, trauma and disasters. 2007:45-59. Tampa, FL. Disaster Life Support Publishing.
Shea MT, McDevitt–Murphy M, Ready DJ, Schnurr PP. Group therapy. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:306-326. New York. Guilford Press.
Sheinberg M, True F. Treating family relational trauma: A recursive process using a decision dialogue. Family Process. 2008;47:173-195. [pmid: 18605120].
Shemesh E, Yehuda R, Milo O, Dinur I, Rudnick A, Vered Z, et al. Posttraumatic stress, nonadherence, and adverse outcome in survivors of a myocardial infarction. Psychosomatic Medicine. 2004;66:521-526. [pmid: 15272097].
Shen YC, Arkes J, Williams TV. Effects of Iraq/Afghanistan deployments on major depression and substance use disorder: Analysis of active duty personnel in the US military. American Journal of Public Health. 2012;102:S80-S87. [pmid: 22390609].
Sher L, Vilens A. 2010. Neurobiology of post-traumatic stress disorder. New York. Nova Biomedical.
Sher L. Traumatic Stress, depression and suicide. Sher L, Vilens A, editors. Neurobiology of post-traumatic stress disorder. 2010:259-270. New York. Nova Biomedical.
Sherbourne CD, Sullivan G, Craske MG, Roy-Byrne P, Golinelli D, Rose RD, et al. Functioning and disability levels in primary care out-patients with one or more anxiety disorders. Psychological Medicine. 2010;40:2059-2068. [pmid: 20146834].
Sherin JE, Nemeroff CB. Post-traumatic stress disorder: The neurobiological impact of psychological trauma. Dialogues in Clinical Neuroscience. 2011;13:263-278. [pmid: 22034143].
Sherman MD, Zanotti DK, Jones DE. Key elements in couples therapy with veterans with combat-related posttraumatic stress disorder. Professional Psychology–Research and Practice. 2005;36:626-633.
Sherrer MV. The role of cognitive appraisal in adaptation to traumatic stress in adults with serious mental illness: A critical review. Trauma, Violence, & Abuse. 2011;12:151-167.
Sholomskas DE, Carroll KM. One small step for manuals: Computer-assisted training in twelve-step facilitation. Journal of Studies on Alcohol. 2006;67:939-945. [pmid: 17061013].
Shoptaw S, Stein JA, Rawson RA. Burnout in substance abuse counselors: Impact of environment, attitudes, and clients with HIV. Journal of Substance Abuse Treatment. 2000;19:117-126. [pmid: 10963923].
Showalter SE. Compassion fatigue: What is it? Why does it matter? Recognizing the symptoms, acknowledging the impact, developing the tools to prevent compassion fatigue, and strengthen the professional already suffering from the effects. American Journal of Hospice & Palliative Medicine. 2010;27:239-242. [pmid: 20075423].
Sijbrandij M, Olff M, Reitsma JB, Carlier IV, Gersons BP. Emotional or educational debriefing after psychological trauma. Randomised controlled trial. British Journal of Psychiatry. 2006;189:150-155. [pmid: 16880485].
Silver RC, Holman EA, McIntosh DN, Poulin M, Gil-Rivas V. Nationwide logitudinal study of psychological responses to September 11. Journal of the American Medical Association. 2002;288:1235-1244. [pmid: 12215130].
Silver RC, Holman EA, McIntosh DN, Poulin M, Gil-Rivas V, Pizarro J. Coping with a national trauma: A nationwide longitudinal study of responses to the terrorist attacks of September 11. 9/11: Mental health in the wake of terrorist attacks. 2006:45-70. New York. Cambridge University Press.
Silver RC, Poulin M, Holman EA, Mclntosh DN, Gil-Rivas V, Pizarro J. Exploring the myths of coping with a national trauma: A longitudinal study of responses to the September 11th terrorist attacks. Journal of Aggression, Maltreatment & Trauma. 2004;9:129-141.
Simon NM, Otto MW, Wisniewski SR, Fossey M, Sagduyu K, Frank E, et al. Anxiety disorder comorbidity in bipolar disorder patients: Data from the first 500 participants in the Systematic Treatment Enhancement Program for Bipolar Disorder (STEP–BD). American Journal of Psychiatry. 2004;161:2222-2229. [pmid: 15569893].
Simpson TL. Women’s treatment utilization and its relationship to childhood sexual abuse history and lifetime PTSD. Substance Abuse. 2002;23:17-30. [pmid: 12444358].
Skinner KM, Kressin N, Frayne S, Tripp TJ, Hankin CS, Miller DR, et al. The prevalence of military sexual assault among female Veterans’ Administration outpatients. Journal of Interpersonal Violence. 2000;15:291-310.
Skopp NA, Reger MA, Reger GM, Mishkind MC, Raskind M, Gahm GA. The role of intimate relationships, appraisals of military service, and gender on the development of posttraumatic stress symptoms following Iraq deployment. Journal of Traumatic Stress. 2011;24:277-286. [pmid: 21547955].
Slattery SM, Goodman LA. Secondary traumatic stress among domestic violence advocates: Workplace risk and protective factors. Violence Against Women. 2009;15:1358-1379. [pmid: 19809098].
Sleat GK, Ardolino AM, Willett KM. Outcome measures in major trauma care: A review of current international trauma registry practice. Emergency Medicine Journal. 2011;28:1008-1012. [pmid: 21890862].
Sledjeski EM, Speisman B, Dierker LC. Does number of lifetime traumas explain the relationship between PTSD and chronic medical conditions? Answers from the National Comorbidity Survey–Replication (NCS–R). Journal of Behavioral Medicine. 2008;31:341-349. [pmid: 18553129].
Smid GE, Mooren TT, van der Mast RC, Gersons BP, Kleber RJ. Delayed posttraumatic stress disorder: Systematic review, meta-analysis, and meta–regression analysis of prospective studies. Journal of Clinical Psychiatry. 2009;70:1572-1582. [pmid: 19607763].
Smid GE, van der Velden PG, Gersons BPR, Kleber RJ. Late–onset posttraumatic stress disorder following a disaster: A longitudinal study. Psychological Trauma: Theory, Research, Practice, and Policy. 2012;4:312-322.
Smid GE, van der Velden PG, Lensvelt-Mulders GJ, Knipscheer JW, Gersons BP, Kleber RJ. Stress sensitization following a disaster: A prospective study. Psychological Medicine. 2011:1-12.
Smith AJ, Kleijn WC, Trijsburg RW, Hutschemaekers GJ. How therapists cope with clients’ traumatic experiences. Torture. 2007;17:203-215. [pmid: 19289893].
Smith BW, Ortiz JA, Steffen LE, Tooley EM, Wiggins KT, Yeater EA, et al. Mindfulness is associated with fewer PTSD symptoms, depressive symptoms, physical symptoms, and alcohol problems in urban firefighters. Journal of Consulting and Clinical Psychology. 2011;79:613-617. [pmid: 21875175].
Smith DW, Christiansen EH, Vincent RD, Hann NE. Population effects of the bombing of Oklahoma City. Journal of the Oklahoma State Medical Association. 1999;92:193-198. [pmid: 10213972].
Smith ME. Bilateral hippocampal volume reduction in adults with post-traumatic stress disorder: A meta-analysis of structural MRI studies. Hippocampus. 2005;15:798-807. [pmid: 15988763].
Smith MW, Schnurr PP, Rosenheck RA. Employment outcomes and PTSD symptom severity. Mental Health Services Research. 2005;7:89-101. [pmid: 15974155].
Smith TC, Wingard DL, Ryan MA, Kritz-Silverstein D, Slymen DJ, Sallis JF. Prior assault and posttraumatic stress disorder after combat deployment. Epidemiology. 2008;19:505-512. [pmid: 18414091].
Smith-Osborne A. Mental health risk and social ecological variables associated with educational attainment for gulf war veterans: Implications for veterans returning to civilian life. American Journal of Community Psychology. 2009;44:327-337. [pmid: 19838786].
Smyth JM, Hockemeyer JR, Tulloch H. Expressive writing and post-traumatic stress disorder: Effects on trauma symptoms, mood states, and cortisol reactivity. British Journal of Health Psychology. 2008;13:85-93. [pmid: 18230238].
Solomon EP, Heide KM. The biology of trauma. Journal of Interpersonal Violence. 2005;20:51-60. [pmid: 15618561].
Solomon Z, Dekel R, Mikulincer M. Complex trauma of war captivity: A prospective study of attachment and post-traumatic stress disorder. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2008;38:1427-1434.
Sommer CA. Vicarious traumatization, trauma-sensitive supervision, and counselor preparation. Counselor Education and Supervision. 2008;48:61-71.
Söndergaard HP, Theorell T. Language acquisition in relation to cumulative posttraumatic stress disorder symptom load over time in a sample of re-settled refugees. Psychotherapy and Psychosomatics. 2004;73:320-323. [pmid: 15292630].
Sotero M. A conceptual model of historical trauma: Implications for public health practice and research. Journal of Health Disparities Research and Practice. 2006;1:93-108.
Southwick SM, Litz BT, Charney D, Friedman M. 2011. Resilience and mental health: Challenges across the lifespan. Cambridge England. Cambridge University Press.
Spasojevic J, Heffer RW, Snyder DK. Effects of posttraumatic stress and acculturation on marital functioning in Bosnian refugee couples. Journal of Traumatic Stress. 2000;13:205-217. [pmid: 10838671].
Spataro J, Mullen PE, Burgess PM, Wells DL, Moss SA. Impact of child sexual abuse on mental health: Prospective study in men and women. British Journal of Psychiatry. 2004;184:416-421. [pmid: 15123505].
Spates CR, Koch E, Cusack K, Pagoto S, Waller S. Eye movement desensitization and reprocessing. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:279-305. New York. Guilford Press.
Spauwen J, Krabbendam L, Lieb R, Wittchen HU, van Os J. Impact of psychological trauma on the development of psychotic symptoms: Relationship with psychosis proneness. British Journal of Psychiatry. 2006;188:527-533. [pmid: 16738342].
Spira JL, Pyne JM, Wiederhold BK. Experiential methods in the treatment of combat PTSD. Figley CR, Nash WP, editors. Combat stress injury: Theory, research, and management. 2007:205-218. New York. Routledge/Taylor & Francis Group.
Spitzer C, Vogel M, Barnow S, Freyberger HJ, Grabe HJ. Psychopathology and alexithymia in severe mental illness: The impact of trauma and posttraumatic stress symptoms. European Archives of Psychiatry and Neurological Sciences. 2007;257:191-196.
Spitzer RL, First MB, Wakefield JC. Saving PTSD from itself in DSM-V. Journal of Anxiety Disorders. 2007;21:233-241. [pmid: 17141468].
Spitzer RL, Rosen GM, Lilienfeld SO. Revisiting the Institute of Medicine report on the validity of posttraumatic stress disorder. Comprehensive Psychiatry. 2008;49:319-320. [pmid: 18555049].
Spitzer RL, Williams JB, Gibbon M. 1987. Structured clinical interview for DSM-III-R—Patient version (SCID-P). New York. New York State Psychiatric Institute, Biometrics Research.
Splevins KA, Cohen K, Joseph S, Murray C, Bowley J. Vicarious posttraumatic growth among interpreters. Qualitative Health Research. 2010;20:1705-1716. [pmid: 20663936].
Sprang G, Clark JJ, Whitt-Woosley A. Compassion fatigue, compassion satisfaction, and burnout: Factors impacting a professional’s quality of life. Journal of Loss and Trauma. 2007;12:259-280.
Stallard P, Velleman R, Salter E, Howse I, Yule W, Taylor G. A randomised controlled trial to determine the effectiveness of an early psychological intervention with children involved in road traffic accidents. Journal of Child Psychology and Psychiatry. 2006;47:127-134. [pmid: 16423143].
Stamm BH. Work Related Secondary Traumatic Stress. PTSD Research Quarterly. 1997;8:1-3.
Stamm BH. 2009. Professional Quality of Life: Compassion Satisfaction and Fatigue Version 5 (ProQOL). Pocatello, ID. ProQOL.org.
Stamm BH, Figley CR. 1996. Compassion satisfaction and fatigue test. Pocatello, ID. Idaho State University.
Stamm H, Friedman M. Cultural diversity in the appraisal and expression of trauma. Shalev AY, Yehuda R, McFarlane AC, editors. International handbook of human response to trauma. 2000:69-85. New York. Kluwer Academic/Plenum Publishers.
Stamm BH, Hudnall AC. Telecommuting to support workers in disasters. Psychological interventions in times of crisis. 2006:99-118. New York. Springer Publishing Publishing Co.
Starr AJ, Smith WR, Frawley WH, Borer DS, Morgan SJ, Reinert CM, et al. Symptoms of posttraumatic stress disorder after orthopaedic trauma. Journal of Bone and Joint Surgery. 2004;86–A:1115-1121.
Steel JL, Dunlavy AC, Stillman J, Pape HC. Measuring depression and PTSD after trauma: Common scales and checklists. Injury. 2011;42:288-300. [pmid: 21216400].
Steel Z, Chey T, Silove D, Marnane C, Bryant RA, van Os M. Association of torture and other potentially traumatic events with mental health outcomes among populations exposed to mass conflict and displacement: A systematic review and meta-analysis. JAMA. 2009;302:537-549. [pmid: 19654388].
Steil R, Jung K, Stangier U. Efficacy of a two-session program of cognitive restructuring and imagery modification to reduce the feeling of being contaminated in adult survivors of childhood sexual abuse: A pilot study. Journal of Behavior Therapy and Experimental Psychiatry. 2011;42:325-329. [pmid: 21367358].
Stein BD, Elliott MN, Jaycox LH, Collins RL, Berry SH, Klein DJ, et al. A national longitudinal study of the psychological consequences of the September 11, 2001 terrorist attacks: Reactions, impairment, and help–seeking. Psychiatry. 2004;67:105-117. [pmid: 15262576].
Stein DJ, Ipser JC. Pharmacotherapy of PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:149-162. Chichester, UK. John Wiley and Sons, Inc.
Stein DJ, Chiu WT, Hwang I, Kessler RC, Sampson N, Alonso J, et al. Cross-national analysis of the associations between traumatic events and suicidal behavior: Findings from the WHO World Mental Health Surveys. PLoS ONE. 2010;5.
Stein DJ, Friedman MJ, Blanco C. 2011. Post-traumatic stress disorder. Chichester, UK. John Wiley and Sons, Inc.
Stein DJ, Ipser JC, Seedat S. Pharmacotherapy for post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2006:CD002795.
Stein DJ, Ipser J, McAnda N. Pharmacotherapy of posttraumatic stress disorder: A review of meta-analyses and treatment guidelines. CNS Spectrums. 2009;14:25-31. [pmid: 19169191].
Stein MB. Dire need for new PTSD pharmacotherapeutics. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:167-170. Chichester, UK. John Wiley and Sons, Inc.
Stein MB, Roy-Byrne PP, Craske MG, Bystritsky A, Sullivan G, Pyne JM, et al. Functional impact and health utility of anxiety disorders in primary care outpatients. Medical Care. 2005;43:1164-1170. [pmid: 16299426].
Stein MB, Walker JR, Hazen AL, Forde DR. Full and partial posttraumatic stress disorder: Findings from a community survey. American Journal of Psychiatry. 1997;154:1114-1119. [pmid: 9247398].
Stewart RE, Chambless DL. Cognitive–behavioral therapy for adult anxiety disorders in clinical practice: A meta-analysis of effectiveness studies. Journal of Consulting and Clinical Psychology. 2009;77:595-606. [pmid: 19634954].
Stewart S. Suicidality, interpersonal trauma and cultural diversity: A review of the literature. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 2005;4(2).
Stewart SH, Conrod PJ. Psychosocial models of functional associations between posttraumatic stress disorder and substance use disorder. Ouimette P, Brown PJ, editors. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. 2003:29-55. Washington, DC. American Psychological Association.
Stewart SH, Ouimette PC, Brown PJ. Gender and the comorbidity of PTSD with substance use disorders. Kimerling R, Ouimette PC, Wolfe J, editors. Gender and PTSD. 2002:233-270. New York. Guilford Press.
Stinson FS, Dawson DA, Goldstein RB, Chou SP, Huang B, Smith SM, et al. Prevalence, correlates, disability, and comorbidity of DSM-IV narcissistic personality disorder: Results from the Wave 2 National Epidemiologic Survey on alcohol and related conditions. Journal of Clinical Psychiatry. 2008;69:1033-1045. [pmid: 18557663].
Stirman SW. The applicability of randomized controlled trials of psychosocial treatments for PTSD to a veteran population. Journal of Psychiatric Practice. 2008;14:199-208. [pmid: 18664888].
Stockdale SE, Wells KB, Tang L, Belin TR, Zhang L, Sherbourne CD. The importance of social context: Neighborhood stressors, stress-buffering mechanisms, and alcohol, drug, and mental health disorders. Social Science & Medicine. 2007;65:1867-1881. [pmid: 17614176].
Stokols D. Translating social ecological theory into guidelines for community health promotion. American Journal of Health Promotion. 1996;10:282-298. [pmid: 10159709].
Stover CS. Domestic violence research: What have we learned and where do we go from here?. Journal of Interpersonal Violence. 2005;20:448-454. [pmid: 15722500].
Stride S, Geffner R, Lincoln A. The physiological and traumatic effects of childhood exposure to intimate partner violence. Geffner R, Griffin D, Lewis J III, editors. Children exposed to violence: Current issues, interventions and research. 2009:80-97. New York. Routledge/Taylor & Francis Group.
Subcommittee on Posttraumatic Stress Disorder of the Committee on Gulf War and Health: Physiologic, Psychologic, and Psychosocial Effects of Deployment-Related Stress. 2006. Posttraumatic stress disorder: Diagnosis and assessment. Washington, DC. The National Academies Press.
Substance Abuse and Mental Health Services Administration. 2007. Prolonged exposure therapy for posttraumatic stress disorders. Rockville, MD. Substance Abuse and Mental Health Services Adminsitration.
Substance Abuse and Mental Health Services Administration. 2010. Eye movement desensitization and reprocessing. Rockville, MD. Substance Abuse and Mental Health Services Adminstration.
Substance Abuse and Mental Health Services Administration. 2011. Leading change: A plan for SAMHSA’s roles and actions 2011–2014. Rockville, MD. Substance Abuse and Mental Health Services Adminstration.
Substance Abuse and Mental Health Services Administration. 2011. Addressing viral hepatitis in people with substance use disorders. Treatment Improvement Protocol (TIP) Series 53 (HHS Publication No SMA 11-4656). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Managing chronic pain in adults with or in recovery from substance use disorders. Treatment Improvement Protocol (TIP) Series 54 (HHS Publication No SMA 11-4661). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Addressing the specific behavioral health needs of men. Treatment Improvement Protocol (TIP) Series 56 (HHS Publication No SMA 13-4736). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Behavioral health services for people who are homeless. Treatment Improvement Protocol (TIP) Series 55 (HHS Publication No SMA 13-4734). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned a). Behavioral health services: Building health, wellness, and quality of life for sustained recovery. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned b). Behavioral health services for American Indians and Alaska Natives. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned c). Improving cultural competence. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned d). Managing anxiety symptoms in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned e). Relapse prevention and recovery promotion in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned f). Reintegration-related behavioral health issues in veterans and military families. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned h). Using telephone- and Web-based technologies in behavioral health settings. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration, Center for Mental Health Services. 2007. Promotion and prevention in mental health: Strengthening parenting and enhancing child resilience. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration& Office of Applied Studies. 2008. Impact of hurricanes Katrina and Rita on substance use and mental health. (Rep No January 31). Rockville, MD. Substance Abuse and Mental Health Services Administration& Office of Applied Studies.
Substance Abuse and Mental Health Services Administration, Trauma and Justice Strategic Initiative. 2012. SAMHSA’s working definition of trauma and guidance for trauma-informed approach. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Sudaryo MK, Besral, Endarti AT, Rivany R, Phalkey R, Marx M, et al. Injury, disability and quality of life after the 2009 earthquake in Padang, Indonesia: A prospective cohort study of adult survivors. Global Health Action. 2012;5.
Sullivan GM, Neria Y. Pharmacotherapy in post-traumatic stress disorder: Evidence from randomized controlled trials. Current Opinion in Investigational Drugs. 2009;10:35-45. [pmid: 19127485].
Sullivan PM, Knutson JF. Maltreatment and disabilities: A population-based epidemiological study. Child Abuse & Neglect. 2000;24:1257-1273. [pmid: 11075694].
Summey JR. The prevention, treatment and mitigation of secondary traumatic stress in emergency personnel dealing with disasters. Annals of the American Psychotherapy Assn. 2001;4:18-21.
Sumter M. Domestic violence and diversity: A call for multucultural services. Journal of Health and Human Services Administration. 2006;29:173-190. [pmid: 17290811].
Suris A, Lind L, Kashner TM, Borman PD. Mental health, quality of life, and health functioning in women veterans: Differential outcomes associated with military and civilian sexual assault. Journal of Interpersonal Violence. 2007;22:179-197. [pmid: 17202575].
Suvak M, Maguen S, Litz BT, Silver RC, Holman EA. Indirect exposure to the September 11 terrorist attacks: Does symptom structure resemble PTSD?. Journal of Traumatic Stress. 2008;21:30-39. [pmid: 18302169].
Swarbrick M. A wellness approach. Psychiatric Rehabilitation Journal. 2006;29:311-314. [pmid: 16689042].
Swinbourne JM, Touyz SW. The co-morbidity of eating disorders and anxiety disorders: A review. European Eating Disorders Review. 2007;15:253-274. [pmid: 17676696].
Symes L, McFarlane J, Frazier L, Henderson-Everhardus MC, McGlory G, Watson KB, et al. Exploring violence against women and adverse health outcomes in middle age to promote women’s health. Critical Care Nursing Quarterly. 2010;33:233-243. [pmid: 20551737].
Taft CT, Vogt DS, Mechanic MB, Resick PA. Posttraumatic stress disorder and physical health symptoms among women seeking help for relationship aggression. Journal of Family Psychology. 2007;21:354-362. [pmid: 17874920].
Taft CT, Walling SM, Howard JM, Monson C. Trauma, PTSD, and partner violence in military families. Risk and resilience in US military families. 2011:195-212. New York. Springer Publishing Science + Business Media.
Tagay S, Herpertz S, Langkafel M, Senf W. Posttraumatic stress disorder in a psychosomatic outpatient clinic. Gender effects, psychosocial functioning, sense of coherence, and service utilization. Journal of Psychosomatic Research. 2005;58:439-446. [pmid: 16026660].
Tam TW, Zlotnick C, Robertson MJ. Longitudinal perspective: Adverse childhood events, substance use, and labor force participation among homeless adults. American Journal of Drug and Alcohol Abuse. 2003;29:829-846. [pmid: 14713142].
Tanielian T, Jaycox LH. 2008. Invisible wounds of war: Psychological and cognitive injuries, their consequences, and services to assist recovery. Santa Monica, CA. RAND Corporation.
Tanielian TL, Jaycox LH, Schell TL, Marshall GN, Burnam MA, Eibner C, et al. 2008. Invisible wounds of war: Summary and recommendations for addressing psychological and cognitive injuries. Santa Monica, CA. RAND Corporation.
Tarakeshwar N, Hansen NB, Kochman A, Fox A, Sikkema KJ. Resiliency among individuals with childhood sexual abuse and HIV: Perspectives on addressing sexual trauma. Journal of Traumatic Stress. 2006;19:449-460. [pmid: 16929500].
Taylor B, Irving HM, Kanteres F, Room R, Borges G, Cherpitel C, et al. The more you drink, the harder you fall: A systematic review and meta-analysis of how acute alcohol consumption and injury or collision risk increase together. Drug and Alcohol Dependence. 2010;110:108-116. [pmid: 20236774].
Taylor LA, Kreutzer JS, Demm SR, Meade MA. Traumatic brain injury and substance abuse: A review and analysis of the literature. Neuropsychological Rehabilitation. 2003;13:165-188. [pmid: 21854333].
Teicher MH. Scars that won’t heal: The neurobiology of child abuse. Scientific American. 2002;286:68-75. [pmid: 11857902].
Teplin LA, McClelland GM, Abram KM, Weiner DA. Crime victimization in adults with severe mental illness: Comparison with the National Crime Victimization Survey. Archives of General Psychiatry. 2005;62:911-921. [pmid: 16061769].
Terrio HP, Nelson LA, Betthauser LM, Harwood JE, Brenner LA. Postdeployment traumatic brain injury screening questions: Sensitivity, specificity, and predictive values in returning soldiers. Rehabilitation Psychology. 2011;56:26-31. [pmid: 21401283].
The APSAC handbook on child maltreatment. 2nd ed. 2002. Thousand Oaks CA. Sage Publications, Inc.
The National Child Traumatic Stress Network. 2012. Psychological first aid. Los Angeles, CA. National Child Traumatic Stess Network.
Thompson EM, Abel WD. Risk and protective factors in the development of post-traumatic stress disorder symptoms among a cohort of students in two tertiary institutions post Hurricane Ivan. West Indian Medical Journal. 2009;58:179-180. [pmid: 21866605].
Thompson MP, Kingree JB. The frequency and impact of violent trauma among pregnant substance abusers. Addictive Behaviors. 1998;23:257-262. [pmid: 9573429].
Thompson RA. 2004. Crisis intervention and crisis management: Strategies that work in schools and communities. New York. Brunner-Routledge.
Thorp SR, Stein MB. Posttraumatic stress disorder and functioning. PTSD Research Quarterly. 2005;16:1-7.
Tjaden P, Thoennes N. 2000. Extent, nature, and consequences of intimate partner violence. Washington, DC. U.S. Department of Justice.
Tolin DF, Foa EB. Sex differences in trauma and posttraumatic stress disorder: A quantitative review of 25 years of research. Psychological Bulletin. 2006;132:959-992. [pmid: 17073529].
Torchalla I, Nosen L, Rostam H, Allen P. Integrated treatment programs for individuals with concurrent substance use disorders and trauma experiences: A systematic review and meta-analysis. Journal of Substance Abuse Treatment. 2012;42:65-77. [pmid: 22035700].
Torchalla I, Strehlau V, Li K, Schuetz C, Krausz M. The association between childhood maltreatment subtypes and current suicide risk among homeless men and women. Child Maltreatment. 2012;17:132-143. [pmid: 22548892].
Toumbourou JW, Hemphill SA, Tresidder J, Humphreys C, Edwards J, Murray D. Mental health promotion and socio–economic disadvantage: Lessons from substance abuse, violence and crime prevention and child health. Health Promotion Journal of Australia. 2007;18:184-190. [pmid: 18201160].
Toussaint DW, VanDeMark NR, Bornemann A, Graeber CJ. Modifications to the trauma recovery and empowerment model (TREM) for substance-abusing women with histories of violence: Outcomes and lessons learned at a Colorado substance abuse treatment center. Journal of Community Psychology. 2007;35:879-894.
Trauma. 2012. Retrieved July 5, 2013, from: http://www.merriam-webster.com/dictionary/trauma.
Treating compassion fatigue. 2002. New York. Brunner-Routledge.
Treating complex traumatic stress disorders: An evidence-based guide. 2009. New York. Guilford Press.
Tri-County Mental Health Services. 2008. You and TRI County: Consumer rights and concerns. Lewiston, ME. Tri-County Mental Health Services.
Triffleman E. Gender differences in a controlled pilot study of psychosocial treatment in substance dependent patients with post-traumatic stress disorder: Design considerations and outcomes. Alcoholism Treatment Quarterly. 2000;18:113-126.
Triffleman E. Implementing substance dependence posttraumatic stress disorder therapy in a community-based methadone clinic. Sorensen JL, Rawson RA, Guydish J, Zweben JE, editors. Research to practice, practice to research: Promoting scientific clinical interchange in drug abuse treatment. 2002:227-248. Washington, DC. American Psychological Association.
Triffleman E. Issues in implementing posttraumatic stress disorder treatment outcome research in community-based treatment programs. Sorensen JL, Rawson RA, Guydish J, Zweben JE, editors. Drug abuse treatment through collaboration: Practice and research partnerships that work. 2003:227-247. American Psychological Association. Washington.
Triffleman EG, Pole N. Future directions in studies of trauma among ethnoracial and sexual minority samples: Commentary. Journal of Consulting and Clinical Psychology. 2010;78:490-497. [pmid: 20658806].
Triffleman EG, Marmar CR, Delucchi KL, Ronfeldt H. Childhood trauma and posttraumatic stress disorder in substance abuse inpatients. Journal of Nervous & Mental Disease. 1995;183:172-176. [pmid: 7891064].
Trippany RL, Kress VEW, Wilcoxon SA. Preventing vicarious trauma: What counselors should know when working with trauma survivors. Journal of Counseling & Development. 2004;82:31-37.
Trippany RL, Wilcoxon SA, Satcher JF. Factors influencing vicarious traumatization for therapists of survivors of sexual victimization. Journal of Trauma Practice. 2003;2:47-60.
Truman JL. 2011. Criminal Victimization 2010.
Tsakanikos E, Bouras N, Costello H, Holt G. Multiple exposure to life events and clinical psychopathology in adults with intellectual disability. Social Psychiatry and Psychiatric Epidemiology. 2007;42:24-28. [pmid: 17080324].
Tucker P, Trautman R. Understanding and treating PTSD: Past, present, and future. Bulletin of the Menninger Clinic. 2000;64:A37-A51. [pmid: 11002529].
Tucker PM, Pfefferbaum B, North CS, Kent A, Burgin CE, Parker DE, et al. Physiologic reactivity despite emotional resilience several years after direct exposure to terrorism. The American Journal of Psychiatry. 2007;164:230-235. [pmid: 17267785].
Tull MT, Gratz KL, Aklin WM, Lejuez CW. A preliminary examination of the relationships between posttraumatic stress symptoms and crack/cocaine, heroin, and alcohol dependence. Journal of Anxiety Disorders. 2010;24:55-62. [pmid: 19767174].
Tummala-Narra P. Conceptualizing trauma and resilience across diverse contexts: A multicultural perspective. Journal of Aggression, Maltreatment & Trauma. 2007;14:33-53.
Turnbull GJ. A review of post-traumatic stress disorder; part I: Historical development and classification. Injury. 1998;29:87-91. [pmid: 10721399].
Twamley EW, Allard CB, Thorp SR, Norman SB, Cissell SH, Berardi KH, et al. Cognitive impairment and functioning in PTSD related to intimate partner violence. Journal of the International Neuropsychological Society. 2009;15:879-887. [pmid: 19703324].
U.S. Committee For Refugees and Immigrants. 2006. World Refugee Survey 2006: Risks and rights. Washington, DC. U.S. Committee for Refugees and Immigrants.
U.S. Committee For Refugees and Immigrants. 2009. World Refugee Survey: 2009. Washington, DC. U.S. Committee for Refugees and Immigrants.
U.S. Department of Health and Human Services. 2003. Developing cultural competence in disaster mental health programs: Guiding principles and recommendations. (Rep No HHS Pub No SMA 3828). Rockville, MD. Center for Mental Health Services, Substance Abuse and Mental Health Services Administration.
U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau. 2010. Child maltreatment 2008. Washington, DC. U.S. Government Printing Office.
U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau. 2011. Child maltreatment 2010. Washington, DC. U. S. Government Printing Office.
U.S. Department of Health and Human Services, Health Resources and Services Administration. 2006. Model trauma system: Planning and evaulation. Washington, DC. U.S. Department of Health and Human Services.
U.S. Department of Housing and Urban Development & Office of Community Planning and Development. 2007. The annual homeless assessment report to Congress. Washington, DC. U.S. Department of Housing and Urban Development.
U.S. Department of Justice. 2010. Criminal victimization in the United States, 2008: Statistical Tables. Washington, DC. U S Department of Justice.
U.S. Fire Administration. 2007. I-35W bridge collapse and response. Washington, DC. U.S. Department of Homeland Security.
Ullman SE, Filipas HH. Predictors of PTSD symptom severity and social reactions in sexual assault victims. Journal of Traumatic Stress. 2001;14:369-389. [pmid: 11469163].
Ullman SE, Filipas HH, Townsend SM, Starzynski LL. Psychosocial correlates of PTSD symptom severity in sexual assault survivors. Journal of Traumatic Stress. 2007;20:821-831. [pmid: 17955534].
Ulmer CS, Edinger JD, Calhoun PS. A multi-component cognitive–behavioral intervention for sleep disturbance in veterans with PTSD: A pilot study. Journal of Clinical Sleep Medicine. 2011;7:57-68. [pmid: 21344046].
Unger WS, Wattenberg MS, Foy DW, Glynn SM. Trauma-focus group therapy: An evidence-based group approach to trauma with adults. Schein LA, Spitz HI, Burlingame GM, Muskin PR, editors. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:731-786. New York. Haworth Press.
United States Department of Veterans Affairs, National Center for PTSD. 2011. Mental health effects following disaster: Risk and resilience factors. White River Junction, VT. National Center for PTSD.
University of South Florida College of Behavioral and Community Sciences. 2012. Creating trauma-informed care environments: An organizational self-assessment. Tampa, FL. Central Florida Behavioral Health Network.
Uomoto JM, Williams RM. Post-acute polytrauma rehabilitation and integrated care of returning veterans: Toward a holistic approach. Rehabilitation Psychology. 2009;54:259-269. [pmid: 19702424].
Updegraff JA, Silver RC, Holman EA. Searching for and finding meaning in collective trauma: Results from a national longitudinal study of the 9/11 terrorist attacks. Journal of Personality and Social Psychology. 2008;95:709-722. [pmid: 18729704].
Urlic I, Simunkovic GT. Working through shame in groups for victims of trauma and war. International Journal of Group Psychotherapy. 2009;59:165-178. [pmid: 19441965].
Urquiza AJ, Goodlin–Jones BL. Child sexual abuse and adult revictimization with women of color. Violence and Victims. 1994;9:223-232. [pmid: 7647044].
Vaishnavi S, Connor K, Davidson JRT. An abbreviated version of the Connor–Davidson Resilience Scale (CD–RISC), the CD–RISC2: Psychometric properties and applications in psychopharmacological trials. Psychiatry Research. 2007;152:293-297. [pmid: 17459488].
Valdez C, Kimerling R, Hyun JK, Mark HF, Saweikis M, Pavao J. Veterans Health Administration mental health treatment settings of patients who report military sexual trauma. Journal of Trauma & Dissociation. 2011;12:232-243. [pmid: 21534093].
Valent P. Diagnosis and treatment of helper stresses, traumas, and illnesses. Figley CR, editor. Treating compassion fatigue. 2002:17-38. New York. Brunner-Routledge.
Valentiner DP, Foa EB, Riggs DS, Gershuny BS. Coping strategies and posttraumatic stress disorder in female victims of sexual and nonsexual assault. Journal of Abnormal Psychology. 1996;105:455-458. [pmid: 8772016].
Van Ameringen M, Patterson B. Shortcomings and future directions of the pharmacotherapy of PTSD. Stein DJ, Friedman MJ, Blanco C, editors. Post-traumatic stress disorder. 2011:164-166. Chichester, UK. John Wiley and Sons, Inc.
Van Breda AD. 2001. Resilience theory: A literature review. Pretoria, South Africa. South African Military Health Service.
van den Berg DPG, van der Gaag M. Treating trauma in psychosis with EMDR: A pilot study. Journal of Behavior Therapy and Experimental Psychiatry. 2012;43:664-671. [pmid: 21963888].
van der Kolk BA, Herron N, Hostetler A. The history of trauma in psychiatry. Psychiatric Clinics of North America. 1994;17:583-600. [pmid: 7824384].
van der Kolk BA, McFarlane AC, Van der Hart O. A general approach to treatment of posttraumatic stress disorder. van der Kolk BA, McFarlane AC, Weisaeth L, editors. Traumatic stress: The effects of overwhelming experience on mind, body, and society. 1996:417-440. New York. Guilford Press.
van der Kolk BA, Spinazzola J, Blaustein ME, Hopper JW, Hopper EK, Korn DL, et al. A randomized clinical trial of eye movement desensitization and reprocessing (EMDR), fluoxetine, and pill placebo in the treatment of posttraumatic stress disorder: Treatment effects and long–term maintenance. Journal of Clinical Psychiatry. 2007;68:37-46. [pmid: 17284128].
van der Kolk B, Roth S, Pelcovitz D, Mandel F. 1993. Complex PTSD: Results of the PTSD field trials for DSM-IV. Washington, DC. American Psychiatric Association.
van der Velden PG, Wittmann L. The independent predictive value of peritraumatic dissociation for PTSD symptomatology after type I trauma: A systematic review of prospective studies. Clinical Psychology Review. 2008;28:1009-1020. [pmid: 18406027].
van der Velden PG, Kleber R, Fournier M, Grievink L, Drogendijk A, Gersons BPR. The association between dispositional optimism and mental health problems among disaster victims and a comparison group: A prospective study. Journal of Affective Disorders. 2007;102:35-45. [pmid: 17239959].
Van Emmerik AAP, Kamphuis JH, Hulsbosch AM, Emmelkamp PMG. Single session debriefing after psychological trauma: A meta-analysis. Lancet. 2002;360:766-771. [pmid: 12241834].
Van AM, Mancini C, Simpson W, Patterson B. Potential use of Internet-based screening for anxiety disorders: A pilot study. Depression and Anxiety. 2010;27:1006-1010. [pmid: 20721902].
VanDeusen KM, Way I. Vicarious trauma: An exploratory study of the impact of providing sexual abuse treatment on clinicians’ trust and intimacy. Journal of Child Sexual Abuse. 2006;15:69-85. [pmid: 16551586].
Varra AA, Follette VM. ACT with posttraumatic stress disorder. Hayes SC, editor. A practical guide to acceptance and commitment therapy. 2005:133-152. New York. Springer Publishing Science + Business Media.
Vasterling JJ, Verfaellie M, Sullivan KD. Mild traumatic brain injury and posttraumatic stress disorder in returning veterans: Perspectives from cognitive neuroscience. Clinical Psychology Review. 2009;29:674-684. [pmid: 19744760].
Vaughn MG, Fu Q, DeLisi M, Beaver KM, Perron BE, Howard MO. Criminal victimization and comorbid substance use and psychiatric disorders in the United States: Results from the NESARC. Annals of Epidemiology. 2010;20:281-288. [pmid: 20097578].
Verger P, Dab W, Lamping DL, Loze JY, Deschaseaux-Voinet C, Abenhaim L, et al. The psychological impact of terrorism: An epidemiologic study of posttraumatic stress disorder and associated factors in victims of the 1995–1996 bombings in France. The American Journal of Psychiatry. 2004;161:1384-1389. [pmid: 15285963].
Vermetten E, Lanius RA. Biological and clinical framework for posttraumatic stress disorder. Handb. Clin. Neurol. 2012;106:291-342. [pmid: 22608629].
Verschuur MJ, Maric M, Spinhoven P. Differences in changes in health-related anxiety between Western and non–Western participants in a trauma-focused study. Journal of Traumatic Stress. 2010;23:300-303. [pmid: 20419742].
Vest JR, Catlin TK, Chen JJ, Brownson RC. Multistate analysis of factors associated with intimate partner violence. American Journal of Preventive Medicine. 2002;22:156-164. [pmid: 11897459].
Vickerman KA, Margolin G. Rape treatment outcome research: Empirical findings and state of the literature. Clinical Psychology Review. 2009;29:431-448. [pmid: 19442425].
Villagonzalo KA, Dodd S, Ng F, Mihaly S, Langbein A, Berk M. The relationship between substance use and posttraumatic stress disorder in a methadone maintenance treatment program. Comprehensive Psychiatry. 2011;52:562-566. [pmid: 21109242].
Vlahov D, Galea S, Ahern J, Resnick H, Kilpatrick D. Sustained increased consumption of cigarettes, alcohol, and marijuana Among Manhattan residents after September 11, 2001. American Journal of Public Health. 2004;94:253-254. [pmid: 14759935].
Vo NM. 2006. The Vietnamese boat people, 1954 and 1975–1992. Jefferson, NC. McFarland & Company.
Vogt DS, Tanner LR. Risk and resilience factors for posttraumatic stress symptomatology in Gulf War I veterans. Journal of Traumatic Stress. 2007;20:27-38. [pmid: 17345645].
Vogt DS, King DW, King LA. Risk pathways for PTSD: Making sense of the literature. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:99-115. New York. Guilford Press.
Vogt DS, Pless AP, King LA, King DW. Deployment stressors, gender, and mental health outcomes among Gulf War I veterans. Journal of Traumatic Stress. 2005;18:272-284. [pmid: 16281224].
Vogt D, Bruce TA, Street AE, Stafford J. Attitudes toward women and tolerance for sexual harassment among reservists. Violence Against Women. 2007;13:879-900. [pmid: 17704049].
Vogt D, Vaughn R, Glickman ME, Schultz M, Drainoni ML, Elwy R, et al. Gender differences in combat-related stressors and their association with postdeployment mental health in a nationally representative sample of U.S. OEF/OIF veterans. Journal of Abnormal Psychology. 2011;120:797-806. [pmid: 21639595].
Von Rueden KT, Hinderer KA, McQuillan KA, Murray M, Logan T, Kramer B, et al. Secondary traumatic stress in trauma nurses: Prevalence and exposure, coping, and personal/environmental characteristics. Journal of Trauma Nursing. 2010;17:191-200. [pmid: 21157252].
Voss Horrell SC, Holohan DR, Didion LM, Vance GT. Treating traumatized OEF/OIF veterans: How does trauma treatment affect the clinician?. Professional Psychology: Research and Practice. 2011;42:79-86.
Waelde LC, Pennington D, Mahan C, Mahan R, Kabour M, Marquett R. Psychometric properties of the Race-related Events Scale. Psychological trauma: Theory, research, practice, and policy. 2010;2:4-11.
Wagner KD, Brief DJ, Vielhauer MJ, Sussman S, Keane TM, Malow R. The potential for PTSD, substance use, and HIV risk behavior among adolescents exposed to Hurricane Katrina. Substance Use & Misuse. 2009;44:1749-1767. [pmid: 19895305].
Wagnild GM, Young HM. Development and psychometric evaluation of the Resilience Scale. Journal of Nursing Measurement. 1993;1:165-178. [pmid: 7850498].
Waldrop AE, Back SE, Verduin ML, Brady KT. Triggers for cocaine and alcohol use in the presence and absence of posttraumatic stress disorder. Addictive Behaviors. 2007;32:634-639. [pmid: 16863682].
Waldrop AE, Santa Ana EJ, Saladin ME, McRae AL, Brady KT. Differences in early onset alcohol use and heavy drinking among persons with childhood and adulthood trauma. The American Journal on Addictions. 2007;16:439-442. [pmid: 18058407].
Walker RL, Clark ME, Sanders SH. The postdeployment multi-symptom disorder: An emerging syndrome in need of a new treatment paradigm. Psychological Services. 2010;7:136-147.
Wall T. Beyond survival: Facing the past, claiming the present. Cross Currents. 2009;12(3).
Walser RD, Westrup D. 2007. Acceptance & commitment therapy for the treatment of post-traumatic stress disorder & trauma-related problems: A practitioner’s guide to using mindfulness & acceptance strategies. Oakland, CA. New Harbinger Publications.
Walser RD. 2004. Disaster Response: Professional and Personal Journeys at the Pentagon. New York. The Association for the Advancement of Behavior Therapy.
Walsh F. 2006. Strengthening family resilience. 2nd ed. New York. Guilford Press.
Walsh F. Traumatic loss and major disasters: Strengthening family and community resilience. Family Process. 2007;46:207-227. [pmid: 17593886].
Walsh K, Blaustein M, Knight WG, Spinazzola J, van der Kolk BA. Resiliency factors in the relation between childhood sexual abuse and adulthood sexual assault in college-age women. Journal of Child Sexual Abuse. 2007;16:1-17. [pmid: 17255074].
Walter KH, Horsey KJ, Palmieri PA, Hobfoll SE. The role of protective self-cognitions in the relationship between childhood trauma and later resource loss. Journal of Traumatic Stress. 2010;23:264-273. [pmid: 20419735].
Wan JJ, Morabito DJ, Khaw L, Knudson MM, Dicker RA. Mental illness as an independent risk factor for unintentional injury and injury recidivism. Journal of Trauma. 2006;61:1299-1304. [pmid: 17159669].
Way I, VanDeusen KM, Cottrell T. Vicarious trauma:predictors of clinicians’ disrupted cognitions about self-esteem and self-intimacy. Journal of Child Sexual Abuse. 2007;16:81-98. [pmid: 18032247].
Way I, VanDeusen KM, Martin G, Applegate B, Jandle D. Vicarious trauma: A comparison of clinicians who treat survivors of sexual abuse and sexual offenders. Journal of Interpersonal Violence. 2004;19:49-71. [pmid: 14680529].
Weathers FW, Keane TM, Foa EB. Assessment and diagnosis of adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:23-61. New York. Guilford Press.
Weathers FW, Litz BT, Herman DS, Huska JA, Keane TM. 1993. The PTSD Checklist: Reliability, validity, and & diagnostic utility. Paper presented at the Annual Meeting of the International Society for Traumatic Stress Studies. San Antonio, TX. October.
Wee DF. Review of trauma and dissociation in a cross-cultural perspective: Not just a North American phenomenon. Traumatology. 2007;13:39-40.
Weinbaum Z, Stratton TL, Chavez G, Motylewski-Link C, Barrera N, Courtney JG. Female victims of intimate partner physical domestic violence (IPP–DV), California 1998. American Journal of Preventive Medicine. 2001;21:313-319. [pmid: 11701303].
Weine S, Danieli Y, Silove D, Ommeren MV, Fairbank JA, Saul J. Guidelines for international training in mental health and psychosocial interventions for trauma exposed populations in clinical and community settings. Psychiatry. 2002;65:156-164. [pmid: 12108139].
Weine S, Kulauzovic Y, Klebic A, Besic S, Mujagic A, Muzurovic J, et al. Evaluating a multiple–family group access intervention for refugees with PTSD. Journal of Marital and Family Therapy. 2008;34:149-164. [pmid: 18412823].
Weiss D, Marmar C. The Impact of Event Scale–revised. Wilson J, Keane T, editors. Assessing psychological trauma and PTSD. 1997:399-411. New York. Guildford Press.
Weiss L, Fabri A, McCoy K, Coffin P, Netherland J, Finkelstein R. A vulnerable population in a time of crisis: Drug users and the attacks on the World Trade Center. Journal of Urban Health: Bulletin of the New York Academy of Medicine. 2002;79:392-403. [pmid: 12200508].
Weiss T, Skelton K, Phifer J, Jovanovic T, Gillespie CF, Smith A, et al. Posttraumatic stress disorder is a risk factor for metabolic syndrome in an impoverished urban population. General Hospital Psychiatry. 2011;33:135-142. [pmid: 21596206].
Weissbecker I, Clark C. The impact of violence and abuse on womens physical health: Can trauma-informed treatment make a difference?. Journal of Community Psychology. 2007;35:909-923.
Wenzel SL, Tucker JS, Elliott MN, Hambarsoomians K, Perlman J, Becker K, et al. Prevalence and co-occurrence of violence, substance use and disorder, and HIV risk behavior: A comparison of sheltered and low-income housed women in Los Angeles County. Preventive Medicine. 2004;39:617-624. [pmid: 15313103].
Wessely S. The role of screening in the prevention of psychological disorders arising after major trauma: Pros and cons. Terrorism and disaster: Individual and community mental health interventions. 2003:121-145. New York. Cambridge University Press.
Wessely S, Bryant RA, Greenberg N, Earnshaw M, Sharpley J, Hughes JH. Does psychoeducation help prevent posttraumatic psychological distress?. Psychiatry: Interpersonal and Biological Processes. 2008;71:287-302.
Westermeyer J. Cross-cultural aspects of substance abuse. Galanter M, Kleber HD, editors. The American Psychiatric Publishing textbook of substance abuse treatment. 3rd ed. 2004:89-98. Washington, DC. American Psychiatric Publishing.
Westermeyer J, Hollifield M, Spring M, Johnson D, Jaranson J. Comparison of two methods of inquiry for torture with East African refugees: Single query versus checklist. Torture. 2011;21:155-172. [pmid: 22057103].
Westphal M, Olfson M, Gameroff MJ, Wickramaratne P, Pilowsky DJ, Neugebauer R, et al. Functional impairment in adults with past posttraumatic stress disorder: Findings from primary care. Depression and Anxiety. 2011;28:686-695. [pmid: 21681868].
Whitbeck LB, Chen X, Hoyt DR, Adams GW. Discrimination, historical loss and enculturation: Culturally specific risk and resiliency factors for alcohol abuse among American Indians. Journal of Studies on Alcohol. 2004;65:409-418. [pmid: 15376814].
White M. 2004. Narrative therapy. New Zealand. Massey University.
Whitfield CL, Anda RF, Dube SR, Felitti VJ. Violent childhood experiences and the risk of intimate partner violence in adults: Assessment in a large health maintenance organization. Journal of Interpersonal Violence. 2003;18:166-185.
Widom CS, Morris S. Accuracy of adult recollections of childhood victimization, Part 2: Childhood sexual abuse. Psychological Assessment. 1997;9:34-46.
Widom CS, DuMont K, Czaja SJ. A prospective investigation of major depressive disorder and comorbidity in abused and neglected children grown up. Archives of General Psychiatry. 2007;64:49-56. [pmid: 17199054].
Wiechelt SA, Gryczynski J. Cultural and historical trauma among Native Americans. Ringel S, Brandell JR, editors. Trauma: Contemporary directions in theory, practice, and research. 2012:191-222. Thousand Oaks, CA. Sage Publications.
Wilcox J, Briones D, Suess L. Auditory hallucinations, posttraumatic stress disorder, and ethnicity. Comprehensive Psychiatry. 1991;32:320-323. [pmid: 1935021].
Wilkinson DM, Blacker SD, Richmond VL, Horner FE, Rayson MP, Spiess A, et al. Injuries and injury risk factors among British army infantry soldiers during predeployment training. Injury Prevention. 2011;17:381-387. [pmid: 21507884].
Williams LM. Recall of childhood trauma: A prospective study of women’s memories of child sexual abuse. Journal of Consulting and Clinical Psychology. 1994;62:1167-1176. [pmid: 7860814].
Wilson DR. Health consequences of childhood sexual abuse. Perspectives in Psychiatric Care. 2010;46:56-64. [pmid: 20051079].
Wilson JP, Keane TM. 2004. Assessing psychological trauma and PTSD. 2nd ed. New York. Guilford Press.
Wilson JP, Tang CS. 2007. Cross-cultural assessment of psychological trauma and PTSD. New York. Springer Publishing.
Wilson JP. The lens of culture: Theoretical and conceptual perspectives in the assessment of psychological trauma and PTSD. Wilson JP, Tang CS, editors. Cross-cultural assessment of psychological trauma and PTSD. 2007:3-30. New York. Springer Publishing Science + Business Media.
Wilson JP. Culture, trauma, and the treatment of post-traumatic syndromes: A global perspective. Marsella AJ, Johnson JL, Watson P, Gryczynski J, editors. Ethnocultural perspectives on disaster and trauma: Foundations, issues, and applications. 2008:351-375. New York. Springer Publishing Science + Business Media.
Wingo AP, Wrenn G, Pelletier T, Gutman AR, Bradley B, Ressler KJ. Moderating effects of resilience on depression in individuals with a history of childhood abuse or trauma exposure. Journal of Affective Disorders. 2010;126:411-414. [pmid: 20488545].
Wittchen HU, Schonfeld S, Thurau C, Trautmann S, Galle M, Mark K, et al. 2012. Prevalence, incidence and determinants of PTSD and other mental disorders: Design and methods of the PID–PTSD+(3) study. International Journal of Methods in Psychiatric Research.
Wolf GK, Reinhard M, Cozolino LJ, Caldwell A, Asamen JK. Neuropsychiatric symptoms of complex posttraumatic stress disorder: A preliminary Minnesota Multiphasic Personality Inventory scale to identify adult survivors of childhood abuse. Psychological Trauma: Theory, Research, Practice, and Policy. 2009;1:49-64.
Wolfe J, Kimerling R. Gender issues in the assessment of posttraumatic stress disorder. Wilson JP, Keane TM, editors. Assessing Psychological Trauma and PTSD. 1997:192-238. New York. Guilford Press.
Wolpe J, Abrams J. Post-traumatic stress disorder overcome by eye-movement desensitization: A case report. Journal of Behavior Therapy and Experimental Psychiatry. 1991;22:39-43. [pmid: 1680883].
Wolpe J. 1958. Psychotherapy by Reciprocal Inhibition. Stanford, CA. Stanford University Press.
Wong EC, Schell TL, Marshall GN, Jaycox LH, Hambarsoomians K, Belzberg H. Mental health service utilization after physical trauma: The importance of physician referral. Medical Care. 2009;47:1077-1083. [pmid: 19648831].
Wong PTP, Wong LCJ. 2006. Handbook of multicultural perspectives on stress and coping. Dallas, TX. Spring Publications.
Woodhead C, Rona RJ, Iversen A, MacManus D, Hotopf M, Dean K, et al. Mental health and health service use among post-national service veterans: Results from the 2007 Adult Psychiatric Morbidity Survey of England. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2011;41:363-372.
Woods SJ. Intimate partner violence and post-traumatic stress disorder symptoms in women: what we know and need to know. Journal of Interpersonal Violence. 2005;20:394-402. [pmid: 15722493].
Woodward AT, Taylor RJ, Bullard KM, Aranda MP, Lincoln KD, Chatters LM. 2011. Prevalence of lifetime DSM-IV affective disorders among older African Americans, Black Caribbeans, Latinos, Asians and non-Hispanic White people. International Journal of Geriatric Psychiatry.
Woon FL, Hedges DW. Amygdala volume in adults with posttraumatic stress disorder: A meta-analysis. Journal of Neuropsychiatry and Clinical Neurosciences. 2009;21:5-12. [pmid: 19359446].
World Health Organization. 1992. International statistical classification of diseases and related health problems. 10th revision ed. Geneva. World Health Organization.
Wrenn GL, Wingo AP, Moore R, Pelletier T, Gutman AR, Bradley B, et al. The effect of resilience on posttraumatic stress disorder in trauma-exposed inner-city primary care patients. Journal of the National Medical Association. 2011;103:560-566. [pmid: 21999030].
Wright DC, Woo WL, Muller RT, Fernandes CB, Kraftcheck ER. An investigation of trauma-centered inpatient treatment for adult survivors of abuse. Child Abuse & Neglect. 2003;27:393-406. [pmid: 12686324].
Wyatt GE, Guthrie D, Notgrass CM. Differential effects of women’s child sexual abuse and subsequent sexual revictimization. Journal of Consulting and Clinical Psychology;Journal of Consulting and Clinical Psychology. 1992;60:167-173.
Xian H, Chantarujikapong SI, Scherrer JF, Eisen SA, Lyons MJ, Goldberg J, et al. Genetic and environmental influences on posttraumatic stress disorder, alcohol and drug dependence in twin pairs. Drug and Alcohol Dependence. 2000;61:95-102. [pmid: 11064187].
Xie Y, Greenman E. 2005. Research report: Segmented assimilation theory: A reformulation and empirical test. Ann Arbor, MI. University of Michigan.
Yanos PT, Czaja SJ, Widom CS. A prospective examination of service use by abused and neglected children followed up into adulthood. Psychiatric Services. 2010;61:796-802. [pmid: 20675838].
Yehuda R, Flory JD. Differentiating biological correlates of risk, PTSD, and resilience following trauma exposure. Journal of Traumatic Stress. 2007;20:435-447. [pmid: 17721957].
Yehuda R. Risk and resilience in posttraumatic stress disorder. Journal of Clinical Psychiatry. Supplement 1. 2004;65:29-36. [pmid: 14728094].
Yehuda R, Bryant R, Zohar J, Marmar CR. Neurobiological and behavioral consequences of terrorism: Distinguishing normal from pathological responses, risk profiling, and optimizing resilience. Bongar B, Brown LM, Beutler LE, Breckenridge JN, Zimbardo PG, editors. Psychology of terrorism. 2007:273-287. New York. Oxford University Press.
Yehuda R, Halligan SL, Bierer LM. Relationship of parental trauma exposure and PTSD to PTSD, depressive and anxiety disorders in offspring. Journal of Psychiatric Research. 2001;35:261-270. [pmid: 11591428].
Yehuda R, Halligan SL, Grossman R. Childhood trauma and risk for PTSD: Relationship to intergenerational effects of trauma, parental PTSD, and cortisol excretion. Development and Psychopathology. 2001;13:733-753. [pmid: 11523857].
Yellow Horse S, Brave, Heart MYH. 2005. Chapter 3: Native American children. Colorado Springs, CO. White Bison, Inc.
Yoder M, Tuerk PW, Price M, Grubaugh AL, Strachan M, Myrick H, et al. Prolonged exposure therapy for combat-related posttraumatic stress disorder: Comparing outcomes for veterans of different wars. Psychological Services. 2012;9:16-25. [pmid: 22449084].
Yoshioka MR, Choi DY. Culture and interpersonal violence research: Paradigm shift to create a full continuum of domestic violence services. Journal of Interpersonal Violence. 2005;20:513-519. [pmid: 15722509].
Young BH. The immediate response to disaster: Guidelines for adult psychological first aid. Ritchie EC, Watson PJ, Friedman MJ, editors. Interventions following mass violence and disasters: Strategies for mental health practice. 2006:134-154. New York. Guilford Press.
Young L. Focus: “Hear me, don’t hurt me”: Survivors teach powerful lessons in trauma and transformation. Cross Currents. 2009;12.
Young MA. 2001. The community crisis response team training manual. Washington, DC. Office for Victims of Crime.
Yuan C, Wang Z, Inslicht SS, McCaslin SE, Metzler TJ, Henn–Haase C, et al. Protective factors for posttraumatic stress disorder symptoms in a prospective study of police officers. Psychiatry Research. 2011;188:45-50. [pmid: 21095622].
Zatzick DF, Jurkovich GJ, Gentilello L, Wisner D, Rivara FP. Posttraumatic stress, problem drinking, and functional outcomes after injury. Archives of Surgery. 2002;137:200-205. [pmid: 11822960].
Zayfert C, Becker CB. Implementation of empirically supported treatment for PTSD: Obstacles and innovations. Behavior Therapist. 2000;23:161-168.
Zayfert C, DeViva JC. Avoiding treatment failures in PTSD. Avoiding treatment failures in the anxiety disorders. 2010:147-168. New York. Springer Publishing, Science + Business Media.
Zemore SE. Re-examining whether and why acculturation relates to drinking outcomes in a rigorous, national survey of Latinos. Alcoholism: Clinical & Experimental Research. 2005;29:2144-2153.
Zinzow HM, Resnick HS, Amstadter AB, McCauley JL, Ruggiero KJ, Kilpatrick DG. Drug-or alcohol-facilitated, incapacitated, and forcible rape in relationship to mental health among a national sample of women. Journal of Interpersonal Violence. 2010;25:2217-2236. [pmid: 20100896].
Zivin K, Bohnert ASB, Mezuk B, Ilgen MA, Welsh D, Ratliff S, et al. Employment status of patients in the VA health system: Implications for mental health services. Psychiatric Services. 2011;62:35-38. [pmid: 21209297].
Zoellner LA, Feeny NC, Eftekhari A, Foa EB. Changes in negative beliefs following three brief programs for facilitating recovery after assault. Depression and Anxiety. 2011;28:532-540. [pmid: 21721072].
Zohar J, Fostick L, Cohen A, Bleich A, Dolfin D, Weissman Z, et al. Risk factors for the development of posttraumatic stress disorder following combat trauma: A semiprospective study. Journal of Clinical Psychiatry. 2009;70:1629-1635. [pmid: 19852906].
Zohar J, Juven-Wetzler A, Sonnino R, Cwikel-Hamzany S, Balaban E, Cohen H. New insights into secondary prevention in post-traumatic stress disorder. Dialogues in Clinical Neuroscience. 2011;13:301-309. [pmid: 22033784].
Zohar J, Sonnino R, Juven-Wetzler A, Cohen H. Can posttraumatic stress disorder be prevented?. CNS Spectrums. 2009;14:44-51. [pmid: 19169193].
Zweig JM, Yahner J, Rossman SB. Does recent physical and sexual victimization affect further substance use for adult drug-involved offenders?. Journal of Interpersonal Violence. 2012;27(12):2348-2372. [pmid: 22328655].