# Links to Select Abstracts

Afifi TO, Asmundson GJG, Taylor S, Jang KL. The role of genes and environment on trauma exposure and posttraumatic stress disorder symptoms: A review of twin studies. Clinical Psychology Review. 2010;30:101-112. [pmid: 19892451].
Agaibi CE, Wilson JP. Trauma, PTSD, and resilience: A review of the literature. Trauma, Violence, & Abuse. 2005;6:195-216.
Agorastos A, Marmar CR, Otte C. Immediate and early behavioral interventions for the prevention of acute and posttraumatic stress disorder. Current Opinion in Psychiatry. 2011;24:526-532. [pmid: 21941180].
Benish SG, Imel ZE, Wampold BE. The relative efficacy of bona fide psychotherapies for treating post–traumatic stress disorder: A meta-analysis of direct comparisons. Clinical Psychology Review. 2008;28:746-758. [pmid: 18055080].
Ben-Zur H. Personal resources of mastery–optimism, and communal support beliefs, as predictors of posttraumatic stress in uprooted Israelis. Anxiety Stress Coping. 2008;21:295-307. [pmid: 18938288].
Bisson JI, Ehlers A, Matthews R, Pilling S, Richards D, Turner S. Psychological treatments for chronic post–traumatic stress disorder: Systematic review and meta-analysis. British Journal of Psychiatry. 2007;190:97-104. [pmid: 17267924].
Breslau N, Davis C, Peterson EL, Schultz L. A second look at comorbidity in victims of trauma: The posttraumatic stress disorder–major depression connection. Biological Psychiatry. 2000;48:902-909. [pmid: 11074228].
Brewin CR, Andrews B, Valentine JD. Meta-analysis of risk factors for posttraumatic stress disorder in trauma-exposed adults. Journal of Consulting and Clinical Psychology. 2000;68:748-766. [pmid: 11068961].
Bryant RA, Moulds ML, Guthrie RM, Dang ST, Mastrodomenico J, Nixon RD, et al. A randomized controlled trial of exposure therapy and cognitive restructuring for posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2008;76:695-703. [pmid: 18665697].
Cahill SP, Foa EB, Hembree EA, Marshall RD, Nacash N. Dissemination of exposure therapy in the treatment of posttraumatic stress disorder. Journal of Traumatic Stress. 2006;19:597-610. [pmid: 17075914].
Chen LP, Murad MH, Paras ML, Colbenson KM, Sattler AL, Goranson EN, et al. Sexual abuse and lifetime diagnosis of psychiatric disorders: Systematic review and meta-analysis. Mayo Clinic Proceedings. 2010;85:618-629. [pmid: 20458101].
Cloitre M. Effective psychotherapies for posttraumatic stress disorder: A review and critique. CNS Spectrums. 2009;14:32-43. [pmid: 19169192].
Cloitre M, Courtois CA, Charuvastra A, Carapezza R, Stolbach BC, Green BL. Treatment of complex PTSD: Results of the ISTSS expert clinician survey on best practices. Journal of Traumatic Stress. 2011;24:615-627. [pmid: 22147449].
Cloitre M, Stovall-McClough KC, Nooner K, Zorbas P, Cherry S, Jackson CL, et al. Treatment for PTSD related to childhood abuse: A randomized controlled trial. American Journal of Psychiatry. 2010;167:915-924. [pmid: 20595411].
Coker AL, Weston R, Creson DL, Justice B, Blakeney P. PTSD symptoms among men and women survivors of intimate partner violence: The role of risk and protective factors. Violence and Victims. 2005;20:625-643. [pmid: 16468442].
Collimore KC, Carleton RN, Hofmann SG, Asmundson GJG. Posttraumatic stress and social anxiety: The interaction of traumatic events and interpersonal fears. Depression and Anxiety. 2010;27:1017-1026. [pmid: 20721907].
Cougle JR, Feldner MT, Keough ME, Hawkins KA, Fitch KE. Comorbid panic attacks among individuals with posttraumatic stress disorder: Associations with traumatic event exposure history, symptoms, and impairment. Journal of Anxiety Disorders. 2010;24:183-188. [pmid: 19914036].
Cukor J, Spitalnick J, Difede J, Rizzo A, Rothbaum BO. Emerging treatments for PTSD. Clinical Psychology Review. 2009;29:715-726. [pmid: 19800725].
Dass-Brailsford P, Myrick AC. Psychological trauma and substance abuse: The need for an integrated approach. Trauma, Violence, & Abuse. 2010;11:202-213.
Difede J, Malta LS, Best S, Henn-Haase C, Metzler T, Bryant R, et al. A randomized controlled clinical treatment trial for World Trade Center attack–related PTSD in disaster workers. Journal of Nervous and Mental Disease. 2007;195:861-865. [pmid: 18043528].
DiGrande L, Neria Y, Brackbill RM, Pulliam P, Galea S. Long–term posttraumatic stress symptoms among 3,271 civilian survivors of the September 11, 2001, terrorist attacks on the World Trade Center. American Journal of Epidemiology. 2011;173:271-281. [pmid: 21190987].
Domino ME, Morrissey JP, Chung S, Huntington N, Larson MJ, Russell LA. Service use and costs for women with co-occurring mental and substance use disorders and a history of violence. Psychiatric Services. 2005;56:1223-1232. [pmid: 16215187].
Drogendijk AN, van der Velden PG, Kleber RJ. Acculturation and post-disaster mental health problems among affected and non–affected immigrants: A comparative study. Journal of Affective Disorders. 2012;138:485-489. [pmid: 22377513].
Dube SR, Anda RF, Felitti VJ, Chapman DP, Williamson DF, Giles WH. Childhood abuse, household dysfunction, and the risk of attempted suicide throughout the life span: Findings from the adverse childhood experiences study. JAMA: The Journal of the American Medical Association. 2001;286:3089-3096. [pmid: 11754674].
Dube SR, Anda RF, Whitfield CL, Brown DW, Felitti VJ, Dong M, et al. Long-term consequences of childhood sexual abuse by gender of victim. American Journal of Preventive Medicine. 2005;28:430-438. [pmid: 15894146].
Ehlers A, Bisson J, Clark DM, Creamer M, Pilling S, Richards D, et al. Do all psychological treatments really work the same in posttraumatic stress disorder?. Clinical Psychology Review. 2010;30:269-276. [pmid: 20051310].
Elwood LS, Mott J, Lohr JM, Galovski TE. Secondary trauma symptoms in clinicians: A critical review of the construct, specificity, and implications for trauma–focused treatment. Clinical Psychology Review. 2011;31:25-36. [pmid: 21130934].
Falsetti SA, Resnick HS, Davis JL. Multiple channel exposure therapy for women with PTSD and comorbid panic attacks. Cognitive Behaviour Therapy. 2008;37:117-130. [pmid: 18470742].
Farley M, Golding JM, Young G, Mulligan M, Minkoff JR. Trauma history and relapse probability among patients seeking substance abuse treatment. Journal of Substance Abuse Treatment. 2004;27:161-167. [pmid: 15450649].
Felmingham KL, Bryant RA. Gender differences in the maintenance of response to cognitive behavior therapy for posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2012;80:196-200. [pmid: 22309472].
Fetzner MG, McMillan KA, Sareen J, Asmundson GJ. What is the association between traumatic life events and alcohol abuse/dependence in people with and without PTSD? Findings from a nationally representative sample. Depression and Anxiety. 2011;28:632-638. [pmid: 21769995].
Foa EB, Zoellner LA, Feeny NC. An evaluation of three brief programs for facilitating recovery after assault. Journal of Traumatic Stress. 2006;19:29-43. [pmid: 16568461].
Geraerts E, Schooler JW, Merckelbach H, Jelicic M, Hauer BJ, Ambadar Z. The reality of recovered memories: Corroborating continuous and discontinuous memories of childhood sexual abuse. Psychological Science. 2007;18:564-568. [pmid: 17614862].
Gillespie CF, Bradley B, Mercer K, Smith AK, Conneely K, Gapen M, et al. Trauma exposure and stress–related disorders in inner city primary care patients. General Hospital Psychiatry. 2009;31:505-514. [pmid: 19892208].
Goldmann E, Aiello A, Uddin M, Delva J, Koenen K, Gant LM, et al. Pervasive exposure to violence and posttraumatic stress disorder in a predominantly African American Urban Community: The Detroit neighborhood health study. Journal of Traumatic Stress. 2011;24:747-751. [pmid: 22144187].
Goodman GS, Ghetti S, Quas JA, Edelstein RS, Alexander KW, Redlich AD, et al. A prospective study of memory for child sexual abuse: New findings relevant to the repressed-memory controversy. Psychological Science. 2003;14:113-118. [pmid: 12661671].
Goodson J, Helstrom A, Halpern JM, Ferenschak MP, Gillihan SJ, Powers MB. The treatment of posttraumatic stress disorder in U.S. combat veterans: A meta-analytic review. Psychological Reports. 2011;109:573-599. [pmid: 22238857].
Guay S, Billette V, Marchand A. Exploring the links between posttraumatic stress disorder and social support: Processes and potential research avenues. Journal of Traumatic Stress. 2006;19:327-338. [pmid: 16788995].
Harned MS, Korslund KE, Foa EB, Linehan MM. Treating PTSD in suicidal and self-injuring women with borderline personality disorder: Development and preliminary evaluation of a Dialectical Behavior Therapy Prolonged Exposure Protocol. Behaviour Research and Therapy. 2012;50:381-386. [pmid: 22503959].
Hinton DE, Kredlow MA, Bui E, Pollack MH, Hofmann SG. Treatment change of somatic symptoms and cultural syndromes among Cambodian refugees with PTSD. Depression and Anxiety. 2012;29:148-155.
Hobfoll SE, Watson P, Bell CC, Bryant RA, Brymer MJ, Friedman MJ, et al. Five essential elements of immediate and mid-term mass trauma intervention: Empirical evidence. Psychiatry. 2007;70:283-315. [pmid: 18181708].
Holbrook TL, Hoyt DB, Stein MB, Sieber WJ. Perceived threat to life predicts posttraumatic stress disorder after major trauma: risk factors and functional outcome. Journal of Trauma. 2001;51:287-292. [pmid: 11493786].
Hopper EK, Bassuk EL, Olivet J. Shelter from the storm: Trauma-informed care in homelessness services settings. The Open Health Services and Policy Journal. 2010;3:80-100.
Ipser JC, Stein DJ. Evidence–based pharmacotherapy of post–traumatic stress disorder (PTSD). International Journal of Neuropsychopharmacology. 2012;15:825-840. [pmid: 21798109].
Johnson H, Thompson A. The development and maintenance of post-traumatic stress disorder (PTSD) in civilian adult survivors of war trauma and torture: A review. Clinical Psychology Review. 2008;28:36-47. [pmid: 17383783].
Kar N. Cognitive behavioral therapy for the treatment of post–traumatic stress disorder: A review. Neuropsychiatric Disease and Treatment. 2011;7:167-181. [pmid: 21552319].
Kessler RC. Posttraumatic stress disorder: the burden to the individual and to society. Journal of Clinical Psychiatry. Supplement 5. 2000;61:4-12. [pmid: 10761674].
Kessler RC, Berglund P, Demler O, Jin R, Merikangas KR, Walters EE. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Archives of General Psychiatry. 2005;62:593-602. [pmid: 15939837].
Kreidler M, Einsporn R. A comparative study of therapy duration for survivors of childhood sexual abuse. Journal of Psychosocial Nursing and Mental Health Services. 2012;50:26-32. [pmid: 22421008].
Krysinska K, Lester D. Post-traumatic stress disorder and suicide risk: A systematic review. Archives of Suicide Research. 2010;14:1-23. [pmid: 20112140].
Laugharne J, Lillee A, Janca A. Role of psychological trauma in the cause and treatment of anxiety and depressive disorders. Current Opinion in Psychiatry. 2010;23:25-29. [pmid: 19901834].
Lester K, Resick PA, Young–Xu Y, Artz C. Impact of race on early treatment termination and outcomes in posttraumatic stress disorder treatment. Journal of Consulting and Clinical Psychology. 2010;78:480-489. [pmid: 20658805].
Levitt JT, Malta LS, Martin A, Davis L, Cloitre M. The flexible application of a manualized treatment for PTSD symptoms and functional impairment related to the 9/11 World Trade Center attack. Behaviour Research and Therapy. 2007;45:1419-1433. [pmid: 17350590].
Marques L, Robinaugh DJ, LeBlanc NJ, Hinton D. Cross-cultural variations in the prevalence and presentation of anxiety disorders. Expert Review of Neurotherapeutics. 2011;11:313-322. [pmid: 21306217].
McDonagh A, Friedman M, McHugo G, Ford J, Sengupta A, Mueser K, et al. Randomized trial of cognitive–behavioral therapy for chronic posttraumatic stress disorder in adult female survivors of childhood sexual abuse. Journal of Consulting and Clinical Psychology. 2005;73:515-524. [pmid: 15982149].
McLean CP, Foa EB. Prolonged exposure therapy for post-traumatic stress disorder: A review of evidence and dissemination. Expert Review of Neurotherapeutics. 2011;11:1151-1163. [pmid: 21797656].
Monson CM, Rodriguez BF, Warner R. Cognitive–behavioral therapy for PTSD in the real world: Do interpersonal relationships make a real difference?. Journal of Clinical Psychology. 2005;61:751-761. [pmid: 15546144].
Morrissey JP, Jackson EW, Ellis AR, Amaro H, Brown VB, Najavits LM. Twelve-month outcomes of trauma-informed interventions for women with co-occurring disorders. Psychiatric Services. 2005;56:1213-1222. [pmid: 16215186].
Mueser KT, Rosenberg SD, Xie H, Jankowski MK, Bolton EE, Lu W, et al. A randomized controlled trial of cognitive–behavioral treatment for posttraumatic stress disorder in severe mental illness. Journal of Consulting & Clinical Psychology. 2008;76:259-271. [pmid: 18377122].
Najavits LM, Harned MS, Gallop RJ, Butler SF, Barber JP, Thase ME, et al. Six-month treatment outcomes of cocaine–dependent patients with and without PTSD in a multisite national trial. Journal of Studies on Alcohol and Drugs. 2007;68:353-361. [pmid: 17446974].
Nappi CM, Drummond SP, Hall JM. Treating nightmares and insomnia in posttraumatic stress disorder: A review of current evidence. Neuropharmacology. 2012;62:576-585. [pmid: 21396945].
Nickerson A, Bryant RA, Silove D, Steel Z. A critical review of psychological treatments of posttraumatic stress disorder in refugees. Clinical Psychology Review. 2011;31:399-417. [pmid: 21112681].
Norris FH, Friedman MJ, Watson PJ. 60,000 disaster victims speak: Part II. Summary and implications of the disaster mental health research. Psychiatry. 2002;65:240-260. [pmid: 12405080].
Norris FH, Friedman MJ, Watson PJ, Byrne CM, Diaz E, Kaniasty K. 60,000 disaster victims speak: Part I. An empirical review of the empirical literature, 1981–2001. Psychiatry. 2002;65:207-239. [pmid: 12405079].
Olff M, Langeland W, Draijer N, Gersons BPR. Gender differences in posttraumatic stress disorder. Psychological Bulletin. 2007;133:183-204. [pmid: 17338596].
Ouimette PC, Brown PJ, Najavits LM. Course and treatment of patients with both substance use and posttraumatic stress disorders. Addictive Behaviors. 1998;23:785-795. [pmid: 9801716].
Ozer EJ, Best SR, Lipsey TL, Weiss DS. Predictors of posttraumatic stress disorder and symptoms in adults: A meta-analysis. Psychological Bulletin. 2003;129:52-73. [pmid: 12555794].
Pietrzak RH, Goldstein RB, Southwick SM, Grant BF. Prevalence and Axis I comorbidity of full and partial posttraumatic stress disorder in the United States: Results from Wave 2 of the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Anxiety Disorders. 2011;25:456-465. [pmid: 21168991].
Ponniah K, Hollon SD. Empirically supported psychological treatments for adult acute stress disorder and posttraumatic stress disorder: A review. Depression and Anxiety. 2009;26:1086-1109. [pmid: 19957280].
Powers MB, Halpern JM, Ferenschak MP, Gillihan SJ, Foa EB. A meta-analytic review of prolonged exposure for posttraumatic stress disorder. Clinical Psychology Review. 2010;30:635-641. [pmid: 20546985].
Resick PA, Galovski TE, O’Brien UM, Scher CD, Clum GA, Young-Xu Y. A randomized clinical trial to dismantle components of cognitive processing therapy for posttraumatic stress disorder in female victims of interpersonal violence. J.Consult Clin.Psychol. 2008;76:243-258. [pmid: 18377121].
Resick PA, Williams LF, Suvak MK, Monson CM, Gradus JL. Long-term outcomes of cognitive–behavioral treatments for posttraumatic stress disorder among female rape survivors. Journal of Consulting and Clinical Psychology. 2012;80:201-210. [pmid: 22182261].
Roberts AL, Austin SB, Corliss HL, Vandermorris AK, Koenen KC. Pervasive trauma exposure among US sexual orientation minority adults and risk of posttraumatic stress disorder. American Journal of Public Health. 2010;100:2433-2441. [pmid: 20395586].
Roberts AL, Gilman SE, Breslau J, Breslau N, Koenen KC. Race/ethnic differences in exposure to traumatic events, development of post–traumatic stress disorder, and treatment–seeking for post–traumatic stress disorder in the United States. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2011;41:71-83.
Roberts NP, Kitchiner NJ, Kenardy J, Bisson J. Multiple session early psychological interventions for the prevention of post-traumatic stress disorder. Cochrane Database of Systematic Reviews. 2009:CD006869. [pmid: 19588408].
Roberts NP, Kitchiner NJ, Kenardy J, Bisson JI. Early psychological interventions to treat acute traumatic stress symptoms. Cochrane Database of Systematic Reviews. 2010:CD007944. [pmid: 20238359].
Robinaugh DJ, McNally RJ. Trauma centrality and PTSD symptom severity in adult survivors of childhood sexual abuse. Journal of Traumatic Stress. 2011;24:483-486. [pmid: 21793046].
Robjant K, Fazel M. The emerging evidence for Narrative Exposure Therapy: A review. Clinical Psychology Review. 2010;30:1030-1039. [pmid: 20832922].
Schnurr PP, Friedman MJ, Foy DW, Shea MT, Hsieh FY, Lavori PW, et al. Randomized trial of trauma-focused group therapy for posttraumatic stress disorder: Results from a Department of Veterans Affairs Cooperative Study. Archives of General Psychiatry. 2003;60:481-489. [pmid: 12742869].
Schottenbauer MA, Glass CR, Arnkoff DB, Gray SH. Contributions of psychodynamic approaches to treatment of PTSD and trauma: A review of the empirical treatment and psychopathology literature. Psychiatry. 2008;71:13-34. [pmid: 18377203].
Schottenbauer MA, Glass CR, Arnkoff DB, Tendick V, Gray SH. Nonresponse and dropout rates in outcome studies on PTSD: Review and methodological considerations. Psychiatry. 2008;71:134-168. [pmid: 18573035].
Seidler GH, Wagner FE. Comparing the efficacy of EMDR and trauma–focused cognitive–behavioral therapy in the treatment of PTSD: A meta-analytic study. Psychological Medicine. 2006;36:1515-1522. [pmid: 16740177].
Shalev AY, Ankri Y, Israeli-Shalev Y, Peleg T, Adessky R, Freedman S. Prevention of posttraumatic stress disorder by early treatment: Results from the Jerusalem Trauma Outreach And Prevention study. Archives of General Psychiatry. 2012;69:166-176. [pmid: 21969418].
Sherin JE, Nemeroff CB. Post-traumatic stress disorder: The neurobiological impact of psychological trauma. Dialogues in Clinical Neuroscience. 2011;13:263-278. [pmid: 22034143].
Sherrer MV. The role of cognitive appraisal in adaptation to traumatic stress in adults with serious mental illness: A critical review. Trauma, Violence, & Abuse. 2011;12:151-167.
Steel JL, Dunlavy AC, Stillman J, Pape HC. Measuring depression and PTSD after trauma: common scales and checklists. Injury. 2011;42:288-300. [pmid: 21216400].
Steel Z, Chey T, Silove D, Marnane C, Bryant RA, van OM. Association of torture and other potentially traumatic events with mental health outcomes among populations exposed to mass conflict and displacement: A systematic review and meta-analysis. JAMA. 2009;302:537-549. [pmid: 19654388].
Stein DJ, Chiu WT, Hwang I, Kessler RC, Sampson N, Alonso J, et al. Cross-national analysis of the associations between traumatic events and suicidal behavior: Findings from the WHO World Mental Health Surveys. PLoS ONE. 2010;5.
Torchalla I, Nosen L, Rostam H, Allen P. Integrated treatment programs for individuals with concurrent substance use disorders and trauma experiences: A systematic review and meta-analysis. Journal of Substance Abuse Treatment. 2012;42:65-77. [pmid: 22035700].
Vasterling JJ, Verfaellie M, Sullivan KD. Mild traumatic brain injury and posttraumatic stress disorder in returning veterans: Perspectives from cognitive neuroscience. Clinical Psychology Review. 2009;29:674-684. [pmid: 19744760].
Verschuur MJ, Maric M, Spinhoven P. Differences in changes in health-related anxiety between Western and non-Western participants in a trauma-focused study. Journal of Traumatic Stress. 2010;23:300-303. [pmid: 20419742].
Vickerman KA, Margolin G. Rape treatment outcome research: Empirical findings and state of the literature. Clinical Psychology Review. 2009;29:431-448. [pmid: 19442425].
Vlahov D, Galea S, Ahern J, Resnick H, Kilpatrick D. Sustained increased consumption of cigarettes, alcohol, and marijuana among Manhattan residents after September 11, 2001. American Journal of Public Health. 2004;94:253-254. [pmid: 14759935].
Walter KH, Horsey KJ, Palmieri PA, Hobfoll SE. The role of protective self-cognitions in the relationship between childhood trauma and later resource loss. Journal of Traumatic Stress. 2010;23:264-273. [pmid: 20419735].
Weine S, Danieli Y, Silove D, Ommeren MV, Fairbank JA, Saul J. Guidelines for international training in mental health and psychosocial interventions for trauma exposed populations in clinical and community settings. Psychiatry. 2002;65:156-164. [pmid: 12108139].
Westermeyer J, Hollifield M, Spring M, Johnson D, Jaranson J. Comparison of two methods of inquiry for torture with East African refugees: Single query versus checklist. Torture. 2011;21:155-172. [pmid: 22057103].
Wrenn GL, Wingo AP, Moore R, Pelletier T, Gutman AR, Bradley B, et al. The effect of resilience on posttraumatic stress disorder in trauma-exposed inner-city primary care patients. Journal of the National Medical Association. 2011;103:560-566. [pmid: 21999030].
Zohar J, Juven-Wetzler A, Sonnino R, Cwikel-Hamzany S, Balaban E, Cohen H. New insights into secondary prevention in post-traumatic stress disorder. Dialogues in Clinical Neuroscience. 2011;13:301-309. [pmid: 22033784].