# Part 3

Section 1 A Review of the Literature

Section 2 Links to Select Abstracts

Section 3 General Bibliography