# An Implementation Guide for Behavioral Health Program Administrators

Chapter 1 Trauma-Informed Organizations

Chapter 2 Building a Trauma-Informed Workforce