# A Practical Guide for the Provision of Behavioral Health Services

Chapter 1 Trauma-Informed Care: A Sociocultural Perspective

Chapter 2 Trauma Awareness

Chapter 3 Understanding the Impact of Trauma

Chapter 4 Screening and Assessment

Chapter 5 Clinical Issues Across Services

Chapter 6 Trauma-Specific Services