# Consensus Panel

Note: Each panelist’s information reflects his or her affiliation at the time of the Consensus Panel meeting and may not reflect that person’s most current affiliation.

## Chair

- Lisa M. Najavits, Ph.D.
  Research Psychologist
  Veterans Affairs Boston Healthcare System
  Professor of Psychiatry
  Boston University School of Medicine
  Boston, MA

## Co-Chair

- Linda B. Cottler, Ph.D., M.P.H.
  Professor of Epidemiology in Psychiatry
  Department of Psychiatry
  Washington University–St. Louis
  St. Louis, MO

## Workgroup Leaders

- Stephanie S. Covington, Ph.D., LCSW, MFCC
  Co-Director
  Center for Gender and Justice
  Institute for Relational Development
  La Jolla, CA
- Margaret Cramer, Ph.D.
  Clinical Psychologist/Clinical Instructor
  Harvard Medical School
  Boston, MA
- Anne M. Herron, M.S.
  Director
  Treatment Programming
  New York State Office of Alcoholism and Substance Abuse Services
  Albany, NY
- Denise Hien, Ph.D.
  Research Scholar
  Social Intervention Group
  School of Social Work
  Columbia University
  New York, NY
- Dee S. Owens, M.P.A.
  Director
  Alcohol-Drug Information
  Indiana University
  Bloomington, IN

## Panelists

- Charlotte Chapman, M.S., LPC, CAC
  Training Director
  Division of Addiction Psychiatry
  Mid-Atlantic Addiction Technology Transfer Center
  Virginia Commonwealth University
  Richmond, VA
- Scott F. Coffey, Ph.D.
  Associate Professor
  Department of Psychiatry and Human Behavior
  University of Mississippi Medical Center
  Jackson, MS
- Renee M. Cunningham-Williams, M.S.W., M.P.E., Ph.D.
  Research Assistant/Professor of Social Work
  Department of Psychiatry
  Washington University
  St. Louis, MO
- Chad D. Emrick, Ph.D.
  Administrative Director
  Substance Abuse Treatment Program
  Denver VA Medical Center (116A1)
  Denver, CO
- Charles R. Figley, Ph.D.
  Professor
  Director of the Traumatology Institute
  Florida State University
  Tallahassee, FL
- Larry M. Gentilello, M.D., FACS
  Professor and Chairman
  Division of Burn, Trauma, and Critical Care
  University of Texas Southwestern Medical School
  Dallas, TX
- Robert Grant, Ph.D.
  Trauma Consultant
  Oakland, CA
- Anthony (Tony) Taiwai Ng, M.D.
  Disaster Psychiatrist
  Washington, DC
- Pallavi Nishith, Ph.D.
  Associate Research Professor
  Center for Trauma
  Department of Psychology
  University of Missouri–St. Louis
  St. Louis, MO
- Joseph B. Stone, Ph.D., CACIII, ICADC
  Program Manager and Clinical Supervisor
  Confederated Tribes of Grand Ronde Behavioral Health Program
  Grand Ronde, OR
- Michael Villanueva, Ph.D.
  Research Professor
  Center on Alcoholism, Substance Abuse, and Addiction
  Albuquerque, NM